# Abbreviations and Acronyms

AAD: Antiarrhythmic drug
AF: Atrial fibrillation
AF-QOL: Atrial Fibrillation Quality of Life Questionnaire
AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
BNP: Brain natriuretic peptide
CER: Comparative effectiveness review
CFAE: Complex fractionated atrial electrogram
CHADS2: Cardiac failure, Hypertension, Age, Diabetes, Stroke system 2
CHF: Congestive heart failure
CI: Confidence interval
CMR: Cardiovascular magnetic resonance
CMS: Centers for Medicare and Medicaid
COI: Conflict of interest
COPD: Chronic obstructive pulmonary disease
EPC: Evidence-based Practice Center
EQ-5D: European Quality of Life Five Dimensions questionnaire
FDA: Food and Drug Administration
F/U: Followup
HR: Hazard ratio
HRQOL: Health-related Quality of Life
IQR: Interquartile range
KCCQ: Kansas City Cardiomyopathy Questionnaire
KQ: Key Question
LA: Left atrial
LV: Left ventricular
LVEF: Left ventricular ejection fraction
MCS: Mental Component Score of the SF-36
METS: Metabolic equivalents
MI: Myocardial infarction
MLHFQ: Minnesota Living with Heart Failure Questionnaire
NA: Not applicable
NR: Not reported
NS: Not statistically significant
PCS: Physical Component Score of the SF-36
PICOTS: Populations, interventions, comparators, outcomes, timing, settings
PVI: Pulmonary vein isolation
QOL: Quality of life
RCT: Randomized controlled trial
RF: Radiofrequency
RFA: Radiofrequency ablation
RNVG: Radionuclide ventriculography
RR: Relative risk
SAS: Zung Self-Rating Anxiety Scale
SD: Standard deviation
SDS: Zung Self-Rating Depression Scale
SF-36: Short Form 36 questionnaire
TEP: Technical Expert Panel
TIA: Transient ischemic attack
TR: Topic refinement
VO_2_: Volume of oxygen