# Executive Summary

## Background

### Nature and Burden of Atrial Fibrillation

Atrial fibrillation (AF) is a major public health concern in the United States, affecting an estimated 2.3 million Americans.1 The prevalence of AF is projected to reach 5.6 to 12.1 million by the year 2050.^2^ AF is the most common sustained arrhythmia seen in clinical practice and accounts for approximately one-third of hospitalizations for cardiac dysrhythmias.3

Atrial fibrillation is characterized by uncoordinated atrial activation with resulting deterioration of atrial mechanical function.4, 5 While AF can occur in isolation, it may also be associated with other arrhythmias such as atrial flutter or atrial tachycardia. Atrial fibrillation can be paroxysmal, persistent, or permanent. The 2014 American College of Cardiology/American Heart Association/Heart Rhythm Society AF guidelines5 defines paroxysmal AF as recurrent AF that terminates spontaneously or with intervention within 7 days of onset, persistent AF as one that is sustained beyond 7 days, and permanent AF as long-standing AF in which restoring and/or maintaining sinus rhythm has failed or has been foregone. Long-standing persistent AF is usually defined as AF that persists for over 1 year. Long-standing persistent and permanent AF is more commonly seen in older patients with structural heart disease.

A number of factors have been associated with increased risk of AF. The prevalence of AF increases with age; it affects 8 to 10 percent of patients 80 years of age and older.2, 6, 7 AF is also more common in males: data from the Framingham Heart Study suggest that men are 1.5 times as likely to develop AF than are women after controlling for age and comorbidities.2 Obesity increases the risk of developing AF. Data from community-based cohorts suggest that obese patients have a 1.5- to 2.3-fold greater risk of developing AF. Furthermore, obesity increases the likelihood that AF will progress from paroxysmal to permanent AF.7 Additional factors associated with an increased risk of AF include smoking, hypertension, hyperthyroidism, obstructive sleep apnea, diabetes, myocardial infarction, heart failure, and cardiac surgery.7

AF is associated with significant mortality, morbidity, and health care costs. Patients with AF have a twofold greater risk of death than do those without this disease. AF is associated with an increased risk of stroke, which affects 5 percent of nonrheumatic AF patients and nearly 7 percent of AF patients with heart failure each year.8 Furthermore, ischemic stroke that occurs in the setting of AF tends to be either fatal or of moderate to high severity in most patients.9 AF can also cause a number of cardiac conditions, including myocardial ischemia or infarction, exacerbation of heart failure, and cardiomyopathy if the ventricular rate is insufficiently controlled.10–13 Although some patients with AF are asymptomatic, other patients experience symptoms like shortness of breath, intractable fatigue, and near-syncope, which can severely affect overall quality of life.14–17 In total, the management of AF and its complications costs the U.S. health care system approximately $26 billion each year.5, 18

### Management of Atrial Fibrillation

Treatment of AF involves rate control, rhythm control, prevention of thromboembolic events, and treating the underlying disease (e.g., hypertension) if applicable.5, 18 Typically, pharmacologic therapy is the primary treatment for rate and rhythm control, while pulmonary vein isolation with catheter ablation is reserved for second-line treatment but may be appropriate as a first-line treatment in select populations when a rhythm control strategy is desired.5 Discussion of strategies to prevent thromboembolic events or to treat underlying causes of AF are beyond the scope of this report.

While the initial management of AF often includes control of ventricular rate using pharmacological agents (i.e., beta-blockers or nonhydropyridine calcium channel blockers), it is common for the long-term management strategy to focus on restoring and maintaining normal heart rhythm.5 AF patients who continue to have significant symptoms despite adequate rate control or who desire long-term rhythm control may be considered for treatment using a rhythm control strategy.

#### Pharmacological Rhythm Control

The primary reason for rhythm control in patients with AF is to improve symptoms. In some patients, adequate rate control is enough to control symptoms, but if patients continue to have symptoms despite good rate control, then rhythm control should be considered. In the absence of symptoms, rhythm control can be used in patients with rapid ventricular response to AF when rate controlling medications are ineffective or cannot be tolerated. Rhythm control should not be used to allow patients to come off anticoagulation as the decision regarding anticoagulation should be based on their risks of thromboembolic events and bleeding.5 Pharmacologic therapy is typically the first choice. Selection of the first-line antiarrhythmic medication is largely driven by the presence or absence of structural heart disease. For example, the 2014 Guidelines for the Management of Patients with Atrial Fibrillation give a Class I recommendation for treatment with flecainide, dofetilide, propafenone, dronedarone, sotalol and amiodarone; but for amiodarone, the guidelines emphasize that because of its potential toxicities, it should only be used after consideration of risks and when other agents have failed or are contraindicated. In patients with heart failure, the guidelines recommend one of two antiarrhythmic medications as first-line therapy (dofetilide and amiodarone).5 Side effects can occur with the use of antiarrhythmic medications; some may actually cause more arrhythmias and some may lose effectiveness over time. Patients on these medications therefore need to be monitored to assess the impact of medications on heart rhythm and the potential for side effects and interactions with any concomitant medications such as anticoagulants.

#### Catheter Ablation Rhythm Control

Catheter ablation for the treatment of AF is increasingly being performed on symptomatic patients as an alternative to medical management, or when medical management has been ineffective or not tolerated.19–21 AF ablation is typically recommended only for symptomatic patients; asymptomatic patients are usually managed with anticoagulation and/or rate control as needed.5 The outcomes of this procedure may depend on patient characteristics such as age, AF type, and presence of structural heart disease, as well as on experience of the operator and methods and technologies used during the procedure. Relief of symptoms is a primary reason for considering catheter ablation as a treatment strategy.

In catheter ablation, energy is sent through an electrode at the tip of a catheter into specific areas of the heart to destroy (ablate) or electrically isolate small areas of tissue where abnormal electrical signals that trigger abnormal heart beats originate. The goal of catheter ablation for treatment of AF is to ablate or isolate triggers that mostly originate in the area of the pulmonary veins. Thus, the most commonly used and recommended catheter ablation procedure to treat AF is pulmonary vein isolation (PVI).19, 22 For the procedure to be successful, complete bi-directional electrical isolation of all pulmonary veins should be achieved. While other approaches may also be used, typically in addition to PVI, there is uncertainty regarding additional benefits or harms of such approaches.19 Recent systematic reviews attempted to evaluate the efficacy of approaches relative to each other,23–25 but significant heterogeneity with regard to the approaches compared precluded meaningful conclusions.23

Among methods and technologies used during the procedure, energy source is an important factor. Currently, there are two US Food and Drug Administration-approved options for catheter ablation: radiofrequency energy, which heats the target sites, and cryoablation, which cools/freezes the sites. Cryoablation may be performed using either a focal catheter (as in radiofrequency ablation [RFA]) or a balloon catheter. How cryoablation compares with RFA in relation to efficacy and safety is also uncertain and is the subject of ongoing debate.

Imaging may be performed before or during the procedure, including magnetic resonance imaging, computed tomography imaging, and transthoracic, trans-esophageal, and intra-cardiac echocardiography. Electroanatomic mapping, which allows for a real-time three-dimensional view of the heart, is often used during the procedure to look for triggers of AF, confirm successful ablation, and allow characterization of its impact on overall left atrial (LA) function. Mapping techniques vary greatly and continue to evolve. Two examples of mapping systems available for use in clinical practice are CARTO (Biosense Webster Inc., CA, USA) and EnSite NavX (St. Jude Medical Inc., MN, USA). The comparative benefits or harms of these techniques are unclear as to date they have not been evaluated in a randomized controlled trial (RCT). Evaluation of imaging and mapping approach is beyond the scope of this report.

#### Scope and Key Questions

In 2009, the Agency for Healthcare Research and Quality (AHRQ) published a comparative effectiveness review that evaluated efficacy, effectiveness and harms of RFA for AF.22 Questions remained regarding evidence on health outcomes beyond one year and the potential impact of RFA on the risk of death and stroke. The comparative effectiveness and harms of catheter ablation in the Medicare population (≥65 years of age or <65 years of age and permanently disabled) were not explored. The 2009 report did not compare cryoablation with medical therapy or compare catheter ablation energy sources with one another.

Based on Medicare Provider Analysis and Review (MedPAR) files, use of catheter ablation for the treatment of atrial fibrillation in the Medicare population increased substantially between 2001 and 2006 from an annual total procedural volume of 135 to 1975 cases and an increase in the number of hospitals performing RFA from 100 to 162.^26^ Annual complication rates increased from 6.7 to 10.1 percent during the same time period, but increasing age was not associated with a higher rate of complications. Procedural volume was associated with probability of in-hospital death but not with overall risk of complications. An almost two-fold increase in the number of patients treated with catheter ablation was reported between 2003 and 2006 compared with the number treated between 1995 and 2002 based on a world-wide survey of electrophysiology centers.27 The authors also report that catheter ablation was increasingly being offered to sicker AF patients. Catheter ablation was reported to be effective in approximately 80 percent of patients. A risk of 4.5 percent for major complications was also reported. Anecdotally, utilization has continued to increase in the Medicare and general populations.

Since the publication of the 2009 AHRQ report, the Catheter Ablation versus Anti-arrhythmic Drug Therapy for Atrial Fibrillation (CABANA) Trial was initiated to directly compare various methods of catheter ablation with medical therapy in a large, multi-center, multi-national trial that includes older patients (over 60 years old) with paroxysmal and persistent atrial fibrillation. (ClinicalTrials.gov identifier NCT00911508); however, final data collection for the primary outcome measure will not be completed until September 2017.

Because there is increasing use of catheter ablation to treat AF patients in the Medicare population as well as uncertainty regarding the efficacy and harms of this procedure in this population in particular, and given that results from CABANA will not be available until 2018 at the earliest, the Centers for Medicare and Medicaid (CMS) has partnered with AHRQ to commission this independent systematic review to evaluate the current state of comparative evidence to help inform clinical practice and policy and to provide insight into research needs and general approaches for addressing identified evidence gaps.

The objective of this review is to evaluate and synthesize current evidence on the comparative effectiveness and harms of catheter ablation for the treatment of AF. For purposes of this report, efficacy refers to the ability of a treatment to produce a desired effect under optimum controlled conditions, such as during a randomized controlled trial. Effectiveness refers to the effect of treatment in actual clinical practice as evaluated by observational studies or comparative pragmatic trials. Comparative effectiveness review is a general term and in this report refers to the conduct and synthesis of systematic research to compare the interventions of interest, incorporating information on efficacy from RCTs and on effectiveness from comparative observational studies. Comparative effectiveness also includes evaluation of adverse events and harms.

The Key Questions used to guide this report are provided below. The analytic framework (Figure A) shows the target population, interventions and outcomes that were examined.

Key Question 1. What is the comparative efficacy and effectiveness of AF catheter ablation on short-term (6 –12 months) and long-term (>12 months) outcomes in the general adult and Medicare populations? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

Key Question 2. What are the comparative short- and long-term complications and harms (e.g., periprocedural or device-related harms) associated with AF catheter ablation in the general adult and Medicare populations? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

Key Question 3. Are there modifications of efficacy, effectiveness, or harms of catheter ablation by patient-level characteristics such as age, sex, type of AF, comorbidities, risk for stroke or bleeding events, condition (i.e., patients with significant left ventricular dysfunction/heart failure or patients with significant left atrial enlargement or left ventricular hypertrophy), provider/setting characteristics, or technique/approach? Comparisons of interest include:

a. Catheter ablation compared with medical therapy
b. Comparing ablation using different energy sources

Figure A Analytic framework for catheter ablation for atrial fibrillation

*Patients with longstanding persistent atrial fibrillation, persistent atrial fibrillation, or paroxysmal atrial fibrillation (considered separately); includes general population and Medicare population.

†Intermediate outcomes are those which may be along the causal pathway to final health outcomes.

BNP = brain natriuretic peptides; HRQOL = health-related quality of life; LA = left atrium; LV = left ventricle; LVEF = left ventricular ejection fraction.

Figure A. This figure, referred to as the analytical framework, depicts the Key Questions addressed in this review. In general, the figure illustrates how the treatments relate to the outcomes and how the outcomes relate to each other. For example, a patient (far left of diagram) presents with atrial fibrillation and may receive medical therapy or catheter ablation (radiofrequency or cryoablation). The treatment can lead to long-term health outcomes (far right of the diagram), intermediate outcomes and harms. The solid lines marked with Key Question numbers are those that this review will evaluate in a comparative way (intervention versus intervention). The dotted line represents the evidence of a relationship between intermediate and health outcomes and is beyond the scope of this review. The bottom box represents Key Question 3, where evidence on variation in outcome based on specific patient characteristics is examined.

## Methods

The methods for this Technology Assessment follow the methods suggested in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews. All methods were determined a priori.28

### Topic Refinement and Systematic Review Protocol

This topic was nominated by CMS as an update to a previous report published in 2009,^22^ particularly to examine longer-term efficacy of catheter ablation and application to the Medicare population in order to inform CMS policy. The AHRQ Task Order Officer functioned as a liaison between the Evidence-based Practice Center (EPC) and CMS and helped resolve any ambiguities regarding the processes or scope of the project. The EPC drafted the initial Key Questions, analytic framework, and inclusion/exclusion criteria and refined them with input from a panel of Key Informants, all of whom were required to disclose any financial or other conflicts of interest prior to participation. The Key Informant panel included experts in cardiology primarily (with specialties in electrophysiology, heart failure, and cardiovascular aging/cardiovascular disease in older adults) and internal medicine; representatives from relevant specialty societies; government representatives (i.e., Department of Veterans Affairs, National Heart, Lung and Blood Institute); and a patient advocate. After review from AHRQ, the draft questions and framework were posted for public review in December 2013 for 3 weeks. Following review of the public commentary, the EPC drafted a final topic refinement document which was approved by AHRQ and posted to their Web site. In place of a Technical Expert Panel, CMS provided input to the Key Questions and scope of the report. The final topic refinement document served as the basis for the review protocol with minor changes. Both the final topic refinement document and the systematic review protocol can be found on the AHRQ Web site at http://www.ahrq.gov/research/findings/ta/. The protocol was also registered with the PROSPERO international database of prospectively registered systematic reviews.

### Literature Search Strategy

A research librarian conducted searches for primary studies in the following databases: Ovid MEDLINE^®^ (from 2005 to November 2014), Cochrane Central (November 2014), and Cochrane Database of Systematic Reviews (from 2005 to November 2014). Searches were limited to a beginning date of January 2005 as there are multiple recent systematic evidence reviews, including good-quality reviews from AHRQ (2013, 2009) 22, 23, 25 and the Washington State Health Technology Assessment Program (2013),22, 23, 25 that have addressed aspects of the Key Questions for this current review, with searches conducted through late 2013. Key Informant input during topic refinement confirmed that this was a logical approach. The search strategy was developed based on an analysis of the medical subject headings (MeSH), terms, and text words of key articles identified a priori (the full search strategy is available in Appendix A). Reference lists of included articles and relevant review articles were inspected for relevant publications. All citations were downloaded and imported into an electronic database (EndNote^®^ X7 Thomson Reuters, Philadelphia, PA).

All citations were reviewed independently by two individuals at both the title/abstract and full-text level and differences were resolved by consensus.

#### Inclusion Exclusion Criteria

Criteria for inclusion and exclusion of studies were based on the Key Questions and the populations, interventions, comparators, outcomes, timing, and setting (PICOTS) approach. Briefly, studies of adult patients with paroxysmal, persistent, or permanent/long-standing AF treated with catheter ablation were sought. For all Key Questions, the focus was on evidence from comparative studies with the least potential for bias. Comparative observational studies were required to have a minimum of 100 patients to be included. Registry and administrative data studies were considered if inclusion criteria were met. Comparators of interest included medical therapy only (i.e., pharmacological agents for rate or rhythm control) and comparisons of different energy sources for catheter ablation (e.g., radiofrequency versus cryoablation). Comparisons of different techniques and/or approaches and mapping were beyond the scope of this report and thus were excluded. For Key Question 2, case series that were specifically designed to evaluate harms and/or adverse events following ablation, had a minimum of 1000 patients and at least 80 percent followup were included because all included comparative studies were relatively small in size. Including these large case series of ablation patients allowed for the calculation of risk estimates of adverse events based on a larger number of patients.

For all Key Questions, both long-term (>12 months) and short-term (≤12 months) outcomes were reported. The primary outcomes (see Rating the Body of Evidence below) were considered to be the most clinically important and were the focus of reporting, decisions for data pooling and determination of overall strength of evidence. Additional outcomes are reported in the detailed evidence synthesis sections of the Key Questions with a focus on outcomes common across studies. Where applicable and where data were available, results from short-term (≤12 months) and long-term (>12 months) followup were described.

Studies published only as conference abstracts, non-English-language articles, and studies of nonhuman subjects were excluded. Studies had to report original data to be included.

#### Study Selection

All citations were independently reviewed by two team members to ensure accuracy. All citations found to be potentially appropriate for inclusion by either reviewer underwent full-text review. Each full-text article was independently evaluated for final inclusion by two investigators. For inclusion, both reviewers had to agree that inclusion criteria were met. Differences between reviewers were resolved through consensus and discussion.

#### Data Extraction

After studies were selected for inclusion, a total of five experienced staff members trained in using the Systematic Review Data Repository (SRDR) database (AHRQ, Rockville, MD; accessed at http://srdr.ahrq.gov/) entered data. After data extraction, at least one other staff member and one study investigator each verified the accuracy and completeness of abstraction for each study included. Discrepancies were resolved by discussion and consensus. SRDR was used to maintain the data and to create detailed evidence tables and summary tables.

### Quality Assessment of Individual Studies

Predefined criteria were used to assess the quality (risk of bias) of included randomized controlled trials and observational studies by using clearly defined templates and criteria as appropriate and following guidance from the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.28 Assessment of RCTs followed appropriate criteria and methods established in the Cochrane Handbook for Systematic Reviews of Interventions.29 Comparative observational studies were assessed for study design features and sources of potential bias. These criteria and methods were used in conjunction with the approach recommended in the chapter, Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions, in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews where in each study was rated as being “good”, “fair”, or “poor” quality.30 Two investigators independently assessed the quality of each study, and any discrepancies were resolved through discussion and consensus.

Studies rated “good” are considered to have the least risk of bias and their results are considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” are susceptible to some bias, though not enough to invalidate the results. These studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others may be only possibly valid.

Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies are least as likely to reflect flaws in the study design as the true difference between the compared interventions. Studies rated as being poor in quality a priori were not excluded, but considered to be less reliable than higher-quality studies when synthesizing the evidence, particularly if discrepancies between studies are present.

Each study evaluated was dual-reviewed for quality by two team members. Any disagreements were resolved by consensus. The final quality assessments are described in detail in Appendix F.

### Data Synthesis

Meta-analysis was conducted in order to provide more precise estimates for outcomes when adequate data were reported. To determine the appropriateness of meta-analysis, clinical and methodological diversity and assessed statistical heterogeneity were considered. A random-effects model was used to combine risk ratios for binary outcomes, mean differences for continuous outcomes (e.g., the Short-Form 36 [SF-36]), and proportions of adverse events that only occurred in the ablation arm, while incorporating variation among studies. For proportions of adverse events, a generalized linear random effects model was used due to sparse data with zero or small number of events. Random effects across studies were assumed, and heterogeneity among the studies was tested based on the random effect variance (τ^2^). Otherwise, a profile-likelihood model was used to combine studies31 and the presence of statistical heterogeneity among the studies was assessed using the standard Cochrane’s chi-square tests and the magnitude of heterogeneity by using the I^2^ statistic.32

To reduce the potential impact of clinical heterogeneity, analyses were stratified by type of AF (paroxysmal, persistent, or mixed population) and length of followup (>12 months versus ≤12 months). Sensitivity analyses were conducted to assess the robustness of results in regards to treatment type (first-line vs. second-line therapy) across all types of atrial fibrillation. For continuous outcomes, results using the mean differences between followup scores were reported as they are slightly more conservative33 and as results based on mean difference in change score were similar. The number of studies was too small for exploring heterogeneity based on study level characteristics (aggregated patient characteristics, comorbidities, quality indicators, etc.). All analyses were performed using Stata/IC 12.1 (StataCorp, College Station, TX) and SAS 9.3 (SAS Institute Inc., Cary, NC).

### Rating the Body of Evidence

The outcomes listed below were considered to be the most relevant and were the focus of reporting, data pooling, and determination of overall strength of evidence. Mortality, stroke and myocardial infarction (MI) occurring after the 30-day peri-procedural period were considered to be efficacy or effectiveness outcomes while such events occurring within the 30-day peri-procedural period were considered adverse events. Primary outcome measures of interest included: mortality (all cause) >30 days postprocedure, stroke (>30 days), MI (>30 days), congestive heart failure (CHF), and health-related quality of life (HRQOL). Intermediate outcome measures of interest included: freedom from recurrence, maintenance of sinus rhythm, and reablation for any arrhythmia (one or more repeat procedures). Primary safety outcomes of interest included: AF (<3 months), mortality (<30 days), stroke (<30 days), cardiac tamponade, pericardial effusion, pulmonary vein stenosis, and adverse drug related events. Outcomes such as pulmonary vein stenosis, cardiac tamponade, and pericardial effusion were considered to be attributable to ablation.

The strength of evidence for each primary efficacy/effectiveness and safety outcome was initially assessed by one researcher using the approach described in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.28, 30

In determining the strength of a body of evidence regarding a given outcome, the following domains were considered: study limitations (the extent to which studies reporting on a particular outcome are likely to be protected from bias, graded as low, medium, or high); consistency (the extent to which studies report the same direction of effect for a particular outcome, graded as consistent, inconsistent, or unknown); directness (whether the outcome is directly or indirectly related to health outcomes of interest, graded as direct or indirect); precision (the level of certainty of the estimate of effect for a particular outcome, including consideration of the sample size and number of events, graded as precise or imprecise); and reporting bias (suspected if there was evidence of selective reporting, otherwise considered to be undetected).

A final strength of evidence grade was assigned by evaluating and weighing the combined results of the above domains; final grades are presented in the Discussion, and tables detailing how final grades were arrived at are available in Appendix G. To ensure consistency and validity of the evaluation, the strength of evidence ratings for all key outcomes were reviewed by the entire team of investigators, and discrepancies were resolved by consensus. Briefly, bodies of evidence consisting of RCTs started as high strength of evidence while bodies of comparative observational studies began as low strength of evidence. The strength of the evidence was then downgraded based on the limitations described above. There are also situations in which the observational evidence may be upgraded (e.g., very large size of effect), but we found no instances in which upgrading could be applied to this body of evidence (see the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews for details on upgrading). A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor-quality studies, extreme inconsistency, or extreme imprecision.

### Applicability

Applicability of the evidence was considered by examining the characteristics of the patient populations included in studies (e.g., demographic characteristics, type of AF, presence of medical comorbidities, stroke risk); the sample size of the studies; and clinical settings (e.g., academic setting, provider experience) in which the studies are performed, as outlined in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.28, 34 Variability in the studies may limit the ability to generalize the results to other populations and settings, for example studies enrolling relatively younger patients with few comorbidities may be less applicable to older patients (i.e., those in the Medicare population).

### Peer Review and Public Commentary

Experts in atrial fibrillation and catheter ablation as well as individuals representing other important stakeholder groups were invited to provide external peer review of this comparative effectiveness review (CER). Comments and editorial review were also provided by the AHRQ Task Order Officer. The draft report was published on the AHRQ Web site for two weeks in order to solicit public comments. At the end of this period, the authors considered both the peer and public review comments and generated a final report. A disposition of comments report detailing the authors' responses to the peer and public review comments will be made available after AHRQ posts the final report of the review on the public Web site.

## Results

### Results of Literature Searches

Database searches identified 3,471 potentially relevant citations. After dual review of abstracts and titles, 103 articles were examined at full text, and of these 46 studies (50 publications) were determined by dual review to meet inclusion criteria and were included in this review. The evidence base in this report includes data from randomized controlled trials as well as observational studies. None of the randomized controlled trials was designed as a pragmatic trial.

#### Key Question 1a Comparative efficacy and effectiveness of radiofrequency catheter ablation versus medical therapy for treatment of atrial fibrillation

Thirteen RCTs35–49 and seven comparative observational studies,50–56 three prospective and four retrospective, compared RFA with medical therapy. Only one RCT was considered to be good quality; the remaining studies were all considered fair quality. No RCT specifically evaluated the Medicare population while two observational studies were comprised of exclusively Medicare-age populations (≥65 years). There was substantial (>35%) crossover from medical therapy to RFA in six trials. Overall, findings from the comparative observational studies were consistent with those reported by the RCTs unless otherwise noted below. See Tables A and B in the Discussion for detailed results.

##### Primary Outcomes

###### Short Term (≤12 months)

In patients with paroxysmal AF, all-cause mortality or MI (low strength of evidence), and stroke or CHF (insufficient strength of evidence) occurring beyond 30 days but before 12 months were rare and there were no statistically significant differences between RFA and medical therapy (low strength of evidence). Overall, there were inconsistencies regarding statistical differences between treatments past 3 months across HRQOL measures used in trials of patient with paroxysmal AF. One analysis of the SF-36 Physical Component Score (PCS) in two RCTs and the Symptom Frequency Severity Scale scores in one RCT suggest improved HRQOL at 12 months. There was insufficient evidence, however, to draw conclusions across trials and measures. Similarly, in patients with persistent AF, the frequency of all-cause mortality (low strength of evidence) or stroke (insufficient strength of evidence) was low with no statistical differences between groups. Again, definitive conclusions regarding improvement across measures of HRQOL were not possible due to the variety of measures and inconsistencies in statistical significance across measures. RFA showed greater improvement than medical therapy in SF-36 PCS in one RCT but no difference in the Atrial Fibrillation Quality of Life Questionnaire were seen in another. Three trials in heart failure patients suggested improvement in the Minnesota Living with Heart Failure Questionnaire at 6 months (low strength of evidence) but only one provided information that this may be sustained to 12 months (insufficient strength of evidence). No studies were identified that reported on short-term outcomes in a Medicare population.

###### Long Term (>12 months)

In patients with paroxysmal AF, all-cause mortality (low strength of evidence), stroke, MI, or CHF (insufficient strength of evidence) were rare in RCTs with no statistical differences between treatment groups. For persistent AF, no evidence was available in the general adult population; however, one comparative observational study in a Medicare-relevant population (mean age of 75.6 ± 5 years) reported comparable frequency of all-cause mortality, stroke or TIA, MI, or CHF between groups (insufficient strength of evidence). A second observational study in Medicare-age patients (mean age 66.9 years) with both paroxysmal and persistent AF reported greater frequency of all-cause mortality, stroke, and CHF in the medical therapy group compared with RFA but a higher frequency of MI following RFA versus medical therapy (insufficient strength of evidence). In the two RCTs reporting SF-36 PCS and MCS beyond 12 months, there were no statistical differences between treatments in patients with paroxysmal AF. Again, firm conclusions were not possible. One large administrative database study reported lower annualized rates of stroke or TIA following RFA compared with medical therapy at 27 months but no difference in hospitalization for heart failure (insufficient strength of evidence).

##### Intermediate Outcomes

###### Short Term (≤12 months)

Across nine RCTs, regardless of AF type, RFA was superior to medical therapy at improving freedom from recurrence of any atrial arrhythmia at 12 months (pooled relative risk [RR] 2.62, 95% confidence interval [CI] 1.90 to 3.96) (moderate strength of evidence). RFA was superior to medical therapy at improving maintenance of sinus rhythm in three RCTs (one in patients with paroxysmal AF and two in heart failure patients with persistent AF) but not in a fourth of paroxysmal AF at 12 months (low strength of evidence for both paroxysmal and persistent AF). The frequency of reablation following RFA varied across seven RCTs of paroxysmal or persistent AF (range, 0% to 53.8%) (low strength of evidence).

###### Long Term (>12 months)

In patients with paroxysmal AF, catheter ablation was superior to medical therapy at improving freedom from recurrence of any atrial arrhythmia based on data from three RCTs (pooled RR 1.24, 95% CI 1.11 to 1.47) (moderate strength of evidence). The frequency of reablation following RFA for paroxysmal AF varied across four RCTs (pooled risk 24.2%, 95% CI 12.6 to 41.5) (low strength of evidence). There were no data for persistent AF patients in the general population for any of the intermediate outcomes. In one comparative observational study of a Medicare-relevant population with persistent AF, sinus rhythm was maintained in 58 percent of the RFA group versus 43 percent of the medical therapy group and 18.3 percent of RFA patients required reablation (insufficient strength of evidence for both).

#### Key Question 1a Comparative efficacy and effectiveness of cryoablation versus medical therapy for treatment of AF

One fair-quality, multi-center RCT compared cryoballoon ablation with medical therapy in a general adult population with paroxysmal or persistent AF (mixed population).57 This study had substantial crossover from medical therapy to cryoballoon ablation. No observational studies were identified for this comparison. Freedom from protocol-defined treatment failure was significantly greater in the cryoballoon ablation group compared with the group treated medically (low strength of evidence). See Table C in the Discussion for detailed results.

#### Key Question 1b Comparative efficacy and effectiveness of cryoablation versus radiofrequency ablation for treatment of atrial fibrillation

Two small RCTs, one fair quality58 and the other poor quality,59 compared cryoballoon ablation with RFA in general adult populations at 12 months. Neither trial reported on the primary outcomes of interest (insufficient strength of evidence). Freedom from AF recurrence was less common following cryoballoon ablation, but the difference wasn’t statistically significant in either the trial in paroxysmal AF patients58 or the trial in a mixed population.59 The need for reablation was more common following cryoballoon ablation in both trials, with the trial in paroxysmal AF patients reporting this as statistically significant (insufficient strength of evidence). Six observational studies (2 fair quality, 4 poor quality) compared cryoballoon ablation to RFA.60–65 No differences between treatments were reported for any of the primary outcomes at 24 months. No differences between treatments for freedom from recurrence were reported across these studies but one poor-quality study in a mixed population reported a higher proportion of patients in the RFA group requiring reablation. Findings from these observational studies did not alter overall strength of evidence. See Tables D and E in the Discussion for detailed results.

#### Key Question 2a Complications and harms associated with radiofrequency catheter ablation versus medical therapy for treatment of atrial fibrillation

All 13 RCTs and six of the comparative observational studies50, 51, 53–56 comparing RFA with medical therapy that were included in Key Question 1a reported adverse events. One observational study was conducted in a Medicare-relevant population (elderly patients, mean age 75.6 years). See Table F in the Discussion for detailed results.

##### Mortality (all-cause) (within 30 days)

The 30-day mortality risk was low and similar for RFA versus medical therapy based on data from five RCTs (low strength of evidence), with similar results in studies of paroxysmal AF patients (3 RCTs) and persistent AF patients (2 RCTs). One prospective comparative observational study of a Medicare-relevant population (age 65 years and older) with persistent AF reported low risk in both treatment groups (insufficient strength of evidence).

##### Stroke (any type) (within 30 days)

Regardless of AF type, the 30-day stroke risk was low following RFA and medical therapy based on data from eight RCTs (low strength of evidence), and no statistical differences between groups were reported. One comparative observational study of a Medicare-relevant population (age 65 years and older) with persistent AF reported higher risk following RFA versus medical therapy (insufficient strength of evidence).

##### AF (within 3 months)

No difference in 3-month AF risk between groups was reported in two RCTs of paroxysmal AF (pooled RR 0.67; 95% CI 0.40 to 1.10) (low strength of evidence), whereas data from two trials of persistent AF patients found a lower 2-month risk of AF following RFA versus medical therapy (pooled RR 0.18; 95% CI 0.11 to 0.30) (low strength of evidence).

##### Cardiac Tamponade

In patients with paroxysmal AF, the pooled risk of cardiac tamponade following RFA was 1.7 percent (95% CI 0.8 to 3.6) based on data from four RCTs (low strength of evidence) while the pooled risk in patients with persistent AF was higher as reported by three small RCTs (5.5%, 95% CI 2.1 to 13.7) (insufficient strength of evidence). One comparative observational study of a Medicare-relevant population (age 65 years and older) with persistent AF reported no events (insufficient strength of evidence).

##### Pericardial Effusion

Regardless of AF type, the risk of pericardial effusion following RFA was low based on data from five RCTs (three RCTs in paroxysmal AF, one in persistent AF, and one in a mixed population): range, 0.5 to 0.9 percent (low strength of evidence for all). One comparative observational study of a Medicare-relevant population (age 65 years and older) with persistent AF reported a risk of 1.9 percent (insufficient strength of evidence).

##### Pulmonary Vein Stenosis

The risk of pulmonary vein stenosis following RFA for treatment of paroxysmal AF ranged from 0 to 3.1 percent across five RCTs; for persistent AF, risk ranged from 0 to 0.9 percent across two RCTs; and for a mixed population in one RCT, no cases were identified (low strength of evidence for all). One comparative observational study of a Medicare-relevant population (age 65 years and older) with persistent AF reported no cases (insufficient strength of evidence).

##### Drug Intolerance Leading to Discontinuation

Overall, 5 to 23 percent of patients with paroxysmal AF randomized to medical therapy discontinued antiarrhythmic drugs due to adverse events or intolerance (2 RCTs) (low strength of evidence). In one RCT of a mixed population, a similar risk was reported between groups (insufficient strength of evidence). One comparative observational study of Medicare-aged patients reported this event in fewer patients in the RFA (2.6%) versus the medical therapy group (12.7%) (insufficient strength of evidence).

#### Key Question 2a Complications and harms associated with cryoablation versus medical therapy for treatment of atrial fibrillation

The RCT comparing cryoballoon ablation with medical therapy in a mixed population (i.e., patients with paroxysmal and persistent AF) included in Key Question 1a reported adverse events. No observational studies were identified for this comparison. There was insufficient evidence from this single study to draw conclusions. Within 30 days of initiation of treatment no deaths were reported for either group and stroke occurred in 0.6 percent in the cryoballoon ablation group, compared with 1.2 percent in the medical treatment group. Over half (51.5%) of cryoablation patients experienced AF recurrence within 3 months of treatment, but no data were reported for the medical therapy group. Following cryoballoon ablation, risk of cardiac tamponade was 0.9 percent and pulmonary vein stenosis was 3.1 percent. See Table G in the Discussion for detailed results.

#### Key Question 2b Complications and harms associated with cryoablation versus radiofrequency catheter ablation for treatment of AF

Two RCTs (one fair quality and one poor quality) plus five nonrandomized comparative studies (one fair-quality and four poor-quality observational studies) comparing cryoballoon ablation with RFA that were included in Key Question 1b reported adverse events. Due largely to lack of RCT data and poor-quality nonrandomized studies, the strength of evidence was insufficient for all outcomes. See Table H in the Discussion for detailed results.

#### Key Question 3 Differential efficacy, effectiveness, or harms of catheter ablation versus medical therapy or different energy sources

All studies described in this Key Question were included in Key Question 1a. Evidence was insufficient to draw conclusions on the potential impact of patient or provider characteristics on the efficacy, effectiveness, or harms of catheter ablation as compared with medical therapy or comparing ablation using different energy sources (insufficient strength of evidence). Studies conducted in specific subgroups of the population found the following: rates of 30-day cerebral thromboembolism and pericardial effusion were higher, but not significantly, with RFA in patients 70 years or older; no differences were seen at 60 days in freedom from recurrence or adverse events. In patients who were receiving RFA as either first- or second-line treatment for AF, both long- and short-term freedom from recurrence rates favored RFA over medical therapy. In patients with heart failure, RFA was associated with improved HRQOL measured via the Minnesota Living with Heart Failure Questionnaire across three studies (low strength of evidence). Two trials reported improved maintenance of sinus rhythm following RFA (50.0%–88.0%) compared with medical therapy (0%–7.7%) at 6 to 12 months. Across the three studies, repeat ablation occurred in 34 percent (95% CI 19.3 to 52.6) of patients. In these studies the rate of major complications following RFA were 4 percent and 15 percent. In patients with Type 2 diabetes, RFA patients had greater improvements in quality of life at 12 months and more patients were free from AF recurrence versus those treated with medical therapy.

## Discussion

### Key Findings and Strength of Evidence

The key findings of this review and strength of evidence for the outcomes identified as being most clinically important are summarized in Tables A–H and factors used to determine the overall strength of evidence are summarized in Appendix G.

Only one RCT was considered to be high quality;42 the remaining RCTs had various methodological limitations. For most Key Questions and outcomes, the strength of evidence was rated no higher than low due to small study sizes and methodological shortcomings. For the comparison of RFA with medical therapy, for the primary clinical outcomes (mortality, stroke, MI, CHF, and HRQOL), all ratings were low or insufficient. Strength of evidence was low or insufficient for most intermediate outcomes as well. Exceptions were freedom from recurrence of any atrial arrhythmia in patients with paroxysmal AF in both the short term (≤12 months) and longer term (>12 months) and for the pooled estimate across all studies regardless of AF type for which the strength of evidence was rated as moderate for the comparison of radiofrequency ablation with medical therapy. For many outcomes for a specific AF type, only single studies were available and conclusions were not possible because of study limitations (i.e., methodology), small sample sizes resulting in imprecise estimates, and/or limited data from these single studies leading to a strength of evidence rating of insufficient. Overall, findings from observational studies did not alter conclusions or impact the strength of evidence for any of the specified outcomes.

Evidence was most robust for the comparison of RFA with medical therapy. Overall, data were sparse for primary clinical outcomes such as mortality and stroke for both the short term and long term. The differences in results for long versus short term, particular with respect to freedom from recurrence and reablation, may be due to a variety of factors including fewer studies reporting longer-term outcome and the short-term followup being too short to capture later relapses, thus longer-term benefit appears lower. There were insufficient data to evaluate the extent to which difference in technique or population characteristics may have impacted outcomes.

In the Medicare-age population, there were no RCTs to provide evidence for efficacy and included trials did not provide subanalysis by age. Definitive conclusions regarding effectiveness could not be drawn from the two comparative observational studies identified that reported on patients aged 65 years and older with followup beyond 12 months.54, 55 Evidence was insufficient for all outcomes. Across these studies comparing RFA with medical therapy, all-cause mortality and hospitalization for CHF after 30 days were greater in the study in a mixed population following RFA but comparable with medical therapy in the study of those with persistent AF. Similar to long-term outcomes in the general population, maintenance of sinus rhythm was more common following RFA (58% vs. 43%) in one study of persistent AF. Reablation was required in 18 percent of patients. In one study of Medicare age patients with persistent AF, there was higher 30-day stroke risk following RFA versus medical therapy (2.6% vs. 0.4%) as well as lower risk of antiarrhythmic drug intolerance requiring discontinuation following RFA (2.6% vs. 12.7%). The inconsistency of these findings and insufficient strength of evidence may make it challenging to weigh overall benefits and risks of RFA compared with medical therapy in this population from an evidence-based perspective.

In the general population, the bulk of evidence was in those with paroxysmal AF, and there were limited data on primary short- and long-term clinical outcomes. In this group, no statistical differences between treatments in all-cause mortality were seen in either the short or long term, but the strength of evidence was low. No differences between treatments for stroke, MI and CHF development were found in the long term but the evidence was from single studies and considered insufficient. Conclusions regarding the impact of RFA on HRQOL in both the long and short term were not possible. This is not to say that there was not improvement in HRQOL or symptoms following ablation, but there are challenges in confirming this with the currently available evidence from comparative studies that met the inclusion criteria. While individual studies reported statistically significant results favoring RFA over medical therapy for specific measures or isolated domains of measures, others did not. The variety of measures used, along with varied measurement timing and extensive cross-over made it difficult to draw firm conclusions regarding the impact of catheter ablation on HRQOL compared with use of anti-arrhythmic drugs as it is difficult to effectively evaluate consistency across measures and effect sizes. This was the basis for the rating of insufficient evidence. Although SF-36 was employed most frequently, measurements occurred at a variety of time points across studies and data were presented in different ways. These factors, combined with possible differences in patients receiving catheter ablation as a first line treatment versus a second line treatment precluded meaningful pooling of data. Where data were pooled, for the SF-36 PCS, different analysis methods yielded differing results, calling the stability of the estimate into question. Across four clinically heterogeneous trials with discrepant time frames (6–48 months), the SF-36 bodily pain domain was significantly more improved in the RFA (vs. medical therapy) groups in three35, 43, 48 of the four trials that provided data, however given the differences in clinical populations and time frames, definitive conclusions are not advisable. The Minnesota Living with Heart Failure Questionnaire (MLHFQ) was reported in three small trials in patients with persistent AF and concomitant heart failure. Two of three studies reported improvement favoring RFA at 6 months; the third didn't reach significance but tended to favor RFA (low strength of evidence). One of the trials reported that the difference was also evident at 12 months (insufficient strength of evidence). For all measures, there was likely insufficient sample size in many studies to detect differences between treatments. Clinically, a primary indication for performing RFA is to improve symptoms. While it may be that patients experience relief of symptoms following RFA, the majority of the HRQOL measures reported may not capture the type and range of symptoms experienced by those with AF or the potential impact of RFA on patient symptoms. There were inadequate data to evaluate the influence of use of RFA as a first versus second-line treatment on HRQOL.

Regarding intermediate outcomes, while moderate evidence indicated that RFA was superior to medical therapy at improving freedom from recurrence, reablation was commonly required and strength of evidence was low for this outcome. Information on utilization was sparse; however, overall rehospitalization for cardiac causes was more common in the medical treatment group.

There were no RCT data on primary outcomes for patients with persistent AF over the long term and a paucity of data over the short term for weighing risks and benefits in this population.

For the comparison of cryoballoon ablation with medical therapy, freedom from protocol-defined treatment failure was significantly more common in the cryoballoon ablation group compared with the group treated medically, but the strength of evidence for this outcome was low. Across the two trials comparing cryoballoon ablation with RFA, freedom from AF was less common and the need for reablation more common following cryoballoon ablation compared with RFA. Failure to demonstrate statistical differences between these energy sources may be partially a function of small sample size and strength of evidence for these outcomes was insufficient.

With regard to harms, in general, no differences between RFA and medical therapy were seen in RCTs for periprocedural harms (those within 30 days), but strength of evidence ranged from low for paroxysmal AF to insufficient for persistent AF, limiting the conclusions that could be drawn. Overall in the general population, risk of any major adverse event within 30 days (all-cause mortality, stroke, myocardial infarction, major bleeding/hemorrhage, need for transfusion and heart failure) from RCTs ranged from 0 to 14.8 percent in those receiving RFA and from 0 to 5.7 percent for those receiving medical therapy. However sample sizes were small and the study that reported that 14.3 percent of RFA procedures had worsening heart failure was based on only 21 patients (3 cases) in advanced heart failure patients. Cardiac tamponade risk ranged from 0 to 4.5 percent following RFA. In studies of patients with heart failure and persistent AF, risks were higher; overall risk of any major complication was 14.8 percent of all procedures in one RCT and risk of cardiac tamponade ranged from 3.8 to 9.5 percent across two RCTs. These overall ranges are from controlled studies conducted in tertiary referral centers with procedures performed by experienced personnel and may not reflect broader clinical practice outside of such centers.

With regard to individual harms, the risk for cardiac tamponade following RFA in patients with paroxysmal AF was imprecise (pooled estimate 1.7%, 95% CI 0.8 to 3.6) and strength of evidence was low, while evidence in patients with persistent AF evidence was insufficient. Overall, 5 to 23 percent of patients with paroxysmal AF who were randomized to medical therapy discontinued antiarrhythmic drugs due to adverse events or intolerance (low strength of evidence). For the comparison of cryoballoon ablation with RFA, there were insufficient quality data to draw firm conclusions.

Conclusions regarding the extent to which catheter ablation may be more efficacious or harmful for specific population subgroups were not possible based on the available evidence. None of the RCTs provided sufficient data to stratify by subgroups. Two studies in patients with concomitant heart failure and persistent AF reported that maintenance of sinus rhythm37, 38 was improved within the ablation patients in the short term and a third trial reported similar results concerning freedom from arrhythmia recurrence;48 however, reablation was common. RFA was associated with improved HRQOL (i.e., MLHFQ) across all three studies37, 38, 48 and with improved functional outcomes in two studies.37, 48 However, given that these studies did not directly compare treatment effect in those who did not have heart failure, modification of treatment effect by presence of heart failure could not be confirmed. Similarly, one study of people who had diabetes as well as either paroxysmal or persistent AF reported a significant benefit in quality of life and freedom from recurrent in ablation patients.35 Again, modification of treatment effect in those with diabetes could not be verified. In the one small study (N=65) in which RFA was used as first-line treatment43 and in the seven trials in which it was used following failure of antiarrhythmic medications,35, 36, 39–42 it appeared that the relative risk point estimates were in the same direction (favoring RFA) for freedom from recurrence to 12 months and that there was substantial overlap in the confidence intervals.35, 36, 39, 40, 42, 47 Similarly, at followup >12 months, the point estimates for the two studies where RFA was used as the first-line treatment were similar to the one study where RFA was used as a second-line treatment, and there was substantial overlap in the confidence intervals.

Table A Key findings and strength of evidence for Key Question 1: Long-term (>12 months) comparative efficacy and effectiveness of RFA versus medical therapy for AF

Outcomes | Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality (All Cause) >30 Days | Paroxysmal AF | 2 RCTs (N=408) | Low | At 24 months, one RCT reported no deaths in either group; the other, two (1.4%) in RFA and four (2.8%) in the medical treatment group.
Mortality (All Cause) >30 Days | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Comparable mortality in both groups at 60 months: 1.3% RFA, 1.9% medical therapy. Definitive conclusions are not possible.^*^
Mortality (All Cause) >30 Days | Mixed | 1 comparative observational (N=170) | Insufficient^*^ | Comparable mortality in both groups at 16 months: 0% RFA, 1.2% medical therapy. Definitive conclusions are not possible.^*^
Mortality (All Cause) >30 Days | Mixed: Medicare population | 1 comparative observational (N=351) | Insufficient^*^ | Greater mortality in the medical therapy arm at 69 months (2.1% RFA, 16.5% medical therapy); Definitive conclusions are not possible.^*^
Stroke >30 Days | Paroxysmal AF | 1 RCT (N=127) | Insufficient^*^ | No strokes reported at 24 months. Definitive conclusions are not possible.^*^
Stroke >30 Days | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Comparable frequency in both groups for stroke or TIA at 60 months (1.3% RFA, 1.9% medical therapy). Definitive conclusions are not possible.^*^
Stroke >30 Days | Mixed | 2 comparative observational (N=1772) | Insufficient^*^ | Increased stroke risk in medical therapy group (0% RFA vs. 4.7% medical therapy at 16 months in one study; annualized rate 3.4% RFA vs. 5.5% medical therapy in an administrative database study with a mean followup of 27 months). Definitive conclusions are not possible.^*^
Stroke >30 Days | Mixed: Medicare population | 1 comparative observational (N=351) | Insufficient^*^ | At 69 months, risk 0% RFA versus 1.5% medical therapy group. Definitive conclusions are not possible.^*^
Myocardial Infarction >30 Days | Paroxysmal AF | 1 RCT (N=294) | Insufficient^*^ | One (0.7%) fatal MI in the medical treatment group by 24 months. Definitive conclusions are not possible.^*^
Myocardial Infarction >30 Days | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Comparable MI events in both groups at 60 months (0% RFA, 0.4 % medical). Definitive conclusions are not possible.^*^
Myocardial Infarction >30 Days | Mixed: Medicare population | 1 comparative observational (N=351) | Insufficient^*^ | Greater MI events in ablation group at 69 months (1.4% RFA, 0% medical therapy). Definitive conclusions are not possible.^*^
Congestive Heart Failure | Paroxysmal AF | 1 RCT (N=294) | Insufficient^*^ | By 24 months, no one in the RFA group and two people (1.4%) in medical therapy group developed CHF. Definitive conclusions are not possible.^*^
Congestive Heart Failure | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Comparable CHF development in both groups at 60 months (0% RFA, 1.2% medical therapy). Definitive conclusions are not possible.^*^
Congestive Heart Failure | Mixed | 1 comparative observational (N=1602) | Insufficient^*^ | Comparable annualized rates of hospitalization for heart failure: 1.5% RFA, 2.2% medical therapy in one administrative data study with a mean followup of 27 months. Definitive conclusions are not possible.^*^
Congestive Heart Failure | Mixed: Medicare population | 1 comparative observational (N=351) | Insufficient^*^ | Greater CHF in medical therapy group at 69 months (0.7% RFA, 9.8% medical therapy). Definitive conclusions are not possible.^*^
Health-Related Quality Of Life: SF-36 | Mental Component Score and Physical Component Score: Paroxysmal AF | 1 RCT (N=294) at 24 months; 1 RCT (N=198) at 48 months | Insufficient^*^ | Mean MCS was similar between groups at 24 months (RFA: 51.1 ± 9.2; Medical therapy: 50.9 ± 8.0) (1 RCT) and at 48 months (RFA: 52.9 ± 9; Medical therapy: 51.9 ± 9) (1 RCT); Mean PCS was similar between groups at 24 months (RFA: 50.0 ± 8.8; Medical therapy: 47.9 ± 8.9) (1 RCT) and at 48 months (RFA: 52.3 ± 9; Medical therapy: 52.6 ± 8) (1 RCT). Definitive conclusions are not possible.^*^
Freedom From Recurrence (Any Arrhythmia) | Paroxysmal AF | 3 RCTs (N=619) | Moderate | At 24–48 months, RFA was associated with greater freedom from recurrence compared with medical therapy (pooled RR 1.24; 95% CI 1.11 to 1.47).
| Mixed | 1 comparative observational N=85 in RFA arm) | Insufficient^*^ | Rate was 74% at 15 months for RFA group; not reported for medical therapy. Definitive conclusions are not possible.^*^
Maintenance Of Sinus Rhythm | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | At 60 months, rate was 58% in the RFA group versus 43% in the medical therapy group. Definitive conclusions are not possible.^*^
Maintenance Of Sinus Rhythm | Mixed | 1 comparative observational (N=170) | Insufficient^*^ | At 15 months, ate was 82% in the RFA group versus 40% in the medical therapy group. Definitive conclusions are not possible.^*^
Reablation (Any Arrhythmia) | Paroxysmal AF | 4 RCTs (N=337) | Low | Over followup periods ranging from longer than 12 months to 48 months, frequency of reablation varied across trials (range, 12.5%–49.2%) with a pooled risk of 24.2% (95% CI 12.6 to 41.5).
Reablation (Any Arrhythmia) | Persistent AF: Medicare population | 1 comparative observational (N=153 ablation group only) | Insufficient^*^ | Rate was 18.3% at 60 months for RFA group; not reported for medical therapy. Definitive conclusions are not possible.^*^

AF = atrial fibrillation; CHF = congestive heart failure; KQ = Key Question; MCS = Mental Component Score; MI = myocardial infarction; PCS = Physical Component Score; RCT = randomized controlled trial; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations (i.e. methodology), small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table B Key findings and strength of evidence for Key Question 1: Short-term (≤12 months) comparative efficacy and effectiveness of RFA versus medical therapy for AF

Outcomes | Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality (All Cause) >30 Days | All RCTs (regardless of AF type) | 7 (N=814) | Low | Low frequency of mortality with risk similar between groups (0%–3.8% for RFA and 0%–2.9% for medical therapy).
Mortality (All Cause) >30 Days | Paroxysmal AF | 3 RCTs (N=333) | Low | One death was reported in the RFA group, two in the medical treatment group.
Mortality (All Cause) >30 Days | Persistent AF | 3 RCTs (N=344) | Low | Two deaths were reported in the RFA group with none reported for medical treatment.
Mortality (All Cause) >30 Days | Mixed | 1 RCT (N=137) | Low | One death was reported in the RFA group and two in the medical therapy group.
Stroke >30 Days | Paroxysmal AF | 1 RCT (N=67) | Insufficient^*^ | No strokes were reported for either treatment. Definitive conclusions are not possible.^*^
Stroke >30 Days | Persistent AF | 1 RCT (N=146) | Insufficient^*^ | No strokes were reported for either treatment. Definitive conclusions are not possible.^*^
Stroke >30 Days | Mixed | 1 RCT (N=70) (Diabetic patients) | Insufficient^*^ | No strokes were reported for either treatment. Definitive conclusions are not possible.^*^
Myocardial Infarction >30 Days | Paroxysmal AF | 2 RCTs (N=270) | Insufficient^*^ | Two fatal MIs occurred, one in each treatment group. Definitive conclusions are not possible.^*^
Congestive Heart Failure | None for any AF type | None | Insufficient | No data available
Health-Related Quality Of Life: SF- 36 | Mental Component Score: Paroxysmal AF | 2 RCTs (N=406); 1 comparative observational (N=166) | Insufficient^*^ | No statistical difference between treatment: pooled estimates for difference in change scores (1.88; 95% CI −0.47 to 4.50) and difference in mean scores (2.26; 95% CI −2.12 to 7.40) based on RCTs.
Health-Related Quality Of Life: SF- 36 | Mental Component Score: Persistent AF (Patients with heart failure) | 1 RCT (N=41) at 6 months | Insufficient^*^ | No difference in mean change from baseline between groups (RFA: +0.4 ± 9.5; Medical Therapy: +5.9 ± 8.5). Definitive conclusions are not possible.^*^
Health-Related Quality Of Life: SF- 36 | Physical Component Score: Paroxysmal AF | 2 RCTs (N=406); 1 comparative observational (N=166) | Insufficient^*^ | No statistical difference between treatments based on the pooled estimate from RCTs for difference in change scores (2.88; 95% CI −0.18 to 5.25); however, RFA was favored based on the pooled estimate using difference in mean scores (2.85; 95% CI 0.93 to 4.82). Definitive conclusions are not possible.^*^
Health-Related Quality Of Life: SF- 36 | Physical Component Score: Persistent AF (Patients with heart failure) | 1 RCT (N=41) at 6 months | Insufficient^*^ | Greater change from baseline for RFA group reached statistical significance (+4.0 ± 9.5 vs. −1.0 ± 4.4 for medical therapy). Definitive conclusions are not possible.^*^
Other Health-Related Quality Of Life Measures | Minnesota Living with Heart Failure Questionnaire: Persistent AF in heart failure patients | 3 RCTs (N=141) (heart failure) | Low (6 months) Insufficient^*^ (12 months) | Two studies reported statistically significant differences favoring RFA at 6 months; means were different in one study (23.7 versus 47.0, p=0.001) and the other provided no data, (p=0.02). No statistical difference between groups (change from baseline −5.7 ± 19.7 for RFA vs. −2.8 ± 17.9) were seen in the third trial but tended to favor RFA. One trial reporting a difference favoring RFA at 6 months which persisted to 12 months. Definitive conclusions beyond 6 months are not possible.^*^
Other Health-Related Quality Of Life Measures | EuroQOL -5D and Symptom Check List: Paroxysmal AF | 1 RCT (N=127) EQ5D; 1 RCT (N=112) Symptom Check List | Insufficient^*^ | Small, single RCTs each reported different measures. No differences between treatments for EQ5D (one trial). Another reported no differences in the Symptom Checklist Frequency Scale but a difference favoring RFA in the Severity Scale. Definitive conclusions are not possible.^*^
Other Health-Related Quality Of Life Measures | AFQOL, KCCQ, and NYHA score: Persistent AF | 1 RCT (N=146) AF-QOL; 1 RCT (N=127) KCCQ; 1 RCT (N=48) NYHA score | Insufficient^*^ | No differences between treatments for AFQOL and KCCQ; RFA favored at 6 months based on NYHA score. Definitive conclusions are not possible.^*^
Other Health-Related Quality Of Life Measures | Zung Self-Rating Anxiety Scale and Depression Scale: Paroxysmal AF | 2 comparative observational (N=365) | Insufficient^*^ | Mean SAS and SDS scores were significantly decreased compared with baseline scores in ablation group but not in the medical group. Magnitude not reported in one study. Definitive conclusions are not possible.^*^
Freedom From Recurrence (Any Arrhythmia) | All RCTs (regardless of AF type) | 9 (N=1089) | Moderate | Freedom from recurrence of any arrhythmia was greater for RFA versus medical therapy (pooled RR 2.62; 95% CI 1.90 to 3.96).
Freedom From Recurrence (Any Arrhythmia) | Paroxysmal AF | 4 RCTs (N=538); 2 comparative observational (N=322) | Moderate | Freedom from recurrence of any arrhythmia was greater for RFA versus medical therapy (pooled RR 3.06; 95% CI 2.35 to 3.90).
Freedom From Recurrence (Any Arrhythmia) | Persistent AF | 3 RCTs (N=344) | Low | Rate is 58%–74% in the RFA group versus 4%–58% in the medical therapy group. Studies are too heterogeneous to combine. Findings are suggestive of benefit, but more data are needed.
Freedom From Recurrence (Any Arrhythmia) | Mixed | 2 RCTs (N=207) | Low | Rate is 56%–80% in the RFA group versus 9%–43% in the medical therapy group. Studies are too heterogeneous to combine. Findings are suggestive of benefit, but more data are needed.
Maintenance Of Sinus Rhythm | Paroxysmal AF | 2 RCTs (N=310); 2 comparative observational (N=385) | Low | Rate is 88%–92.9% for RFA group versus 35.4%–87% for medical therapy arm across RCTs; Rate is 71.1%–72% in the RFA arm vs. 20.2%–47.1% in the medical therapy arm in comparative observational studies.
Maintenance Of Sinus Rhythm | Persistent AF (patients with heart failure) | 2 RCTs (N=93) | Low | Rate 50.0%–88.0% for RFA group versus. 0%–7.7% for medical therapy group.
Reablation (Any Arrhythmia) | All RCTs (regardless of AF type) | 8 (N=430) (ablation group only) | Low | The frequency of reablation following RFA varied across eight RCTs (range, 0%–53.8%).
Reablation (Any Arrhythmia) | Paroxysmal AF | 3 RCTs (N=184); 1 comparative observational (N=82) (ablation groups only) | Low | Rates varied widely (0%–43.3%) and consequently were not pooled.
Reablation (Any Arrhythmia) | Persistent AF | 5 RCTs (N=246) (ablation group only) | Low | Rates ranged from 8.1%–53.8% with a pooled estimate of 25.5% (95% CI 13.6% to 42.6%).
Reablation (Any Arrhythmia) | Persistent AF (patients with heart failure) | 3 RCTs (N=71 ) (ablation group only) | Low | Pooled estimate: 34% (95% CI 19.3% to 52.6%).

AF = atrial fibrillation; AFQOL = Atrial Fibrillation Quality of Life Questionnaire; KCCQ = Kansas City Cardiomyopathy Questionnaire; KQ = Key Question; MCS = Mental Component Score; MI = myocardial infarction; PCS = Physical Component Score; RCT = randomized controlled trial; RFA = radiofrequency ablation; SAS = Zung Self-Rating Anxiety Scale; SDS = Zung Self-Rating Depression Scale.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table C Key findings and strength of evidence for Key Question 1: Short-term (≤12 months) efficacy and effectiveness outcomes comparing cryoballoon ablation with medical therapy for AF

Outcomes^*^ | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality (All Cause) >30 Days | 1 RCT (N=245) | Insufficient^†^ | One unrelated fatal MI at 10 months reported in the cryoballoon ablation group. Definitive conclusions are not possible.^†^
Stroke >30 Days | 1 RCT (N=245) | Insufficient^†^ | Three strokes occurred >30 days from randomization (with one being 5 days after repeat RFA for atrial flutter). Definitive conclusions are not possible.^†^
Myocardial Infarction >30 Days | 1 RCT (N=245) | Insufficient^†^ | One unrelated fatal MI at 10 months reported in the cryoballoon ablation group. Definitive conclusions are not possible.^†^
Congestive Heart Failure | 1 RCT (N=245) | Insufficient^†^ | One cryoballoon ablation patient was hospitalized with AF-related congestive heart failure. Definitive conclusions are not possible.^†^
Health-Related Quality Of Life | 1 RCT (N=245) | Insufficient^†^ | Reported that SF-36 symptoms improved in cryoballoon ablation population but did not publish data or include comparison with medically treated patients. Definitive conclusions are not possible.^†^
Freedom From Protocol-Defined Treatment Failure | 1 RCT (N=245) | Low | Cryoballoon ablation was associated with greater freedom from protocol-defined treatment failure compared with medical therapy: 69.9% versus 7.3%.

AF = atrial fibrillation; KQ = Key Question; MI = myocardial infarction; RCT = randomized controlled trial; RFA = radiofrequency ablation; SF-36 = Short-Form 36 questionnaire.

* All outcomes are for the same RCT in a mixed population (no other studies were identified for this comparison).

† Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table D Key findings and strength of evidence for Key Question 1: Long-term (>12 months) efficacy and effectiveness outcomes comparing cryoballoon ablation with RFA for AF

Outcomes, Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality (all cause) >30 days (Paroxysmal AF) | 1 comparative observational (N=396) | Insufficient^*^ | At 23 months, mortality occurred in 1.2% (3/260) in the RFA arm versus none (0/136) in the cryoballoon ablation arm. Definitive conclusions are not possible.^*^
Freedom from recurrence (any arrhythmia) (Paroxysmal AF) | 2 comparative observational (N=498) | Insufficient^*^ | No statistical differences at 23–28 months with 55%–63% experiencing freedom from recurrence following cryoballoon ablation versus 55%–57% following RFA. Definitive conclusions are not possible.^*^
Reablation (AF only) (Mixed) | 1 comparative observational (N=177) | Insufficient^*^ | By 14 months, reablation for AF was performed in 14% of cryoballoon recipients versus 23% of those receiving RFA. Definitive conclusions are not possible.^*^

AF = atrial fibrillation; KQ = Key Question; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table E Key findings and strength of evidence for Key Question 1: Short-term (≤12 months) efficacy and effectiveness outcomes comparing cryoballoon ablation with RFA for AF

Outcomes | Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Freedom From Recurrence (AF only) | Paroxysmal AF | 1 RCT (N=50); 1 comparative observational (N=143) | Insufficient^*^ | Freedom from AF recurrence was less common in the cryoballoon ablation group (48%) versus RFA (68%) in one RCT, however results failed to reach statistical significance. Rates were 77% and 72%, respectively, in one comparative observational study. Definitive conclusions are not possible^*^
Freedom From Recurrence (AF only) | Mixed | 1 RCT (N=60) | Insufficient^*^ | Freedom from AF recurrence was less common in the cryoballoon ablation group (66.7%) versus RFA (86.7%) however results failed to reach statistical significance. Definitive conclusions are not possible.^*^
Reablation (AF only) | Paroxysmal AF | 1 RCT (N=50) | Insufficient^*^ | Reablation for AF only was more common following cryoballoon ablation (24%) versus none for RFA (0%); RR 0.22 (95% CI 0.07 to 0.37), p=0.0122. Definitive conclusions are not possible.^*^
Reablation (AF only) | Mixed | 1 RCT (N=60) | Insufficient^*^ | Reablation for AF only was more common following cryoballoon ablation (30%) versus RFA (13.3%), but statistical significance was not reached. Definitive conclusions are not possible.^*^

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes resulting in low precision of estimates and/or limited data from single studies.

Table F Key findings and strength of evidence for Key Question 2: Comparative short-term and long-term complications and harms associated with RFA versus medical therapy for AF

Harms/ complications | Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality <30 Days | All RCTs (regardless of AF type) | 5 RCTs (N=761) | Low | Low frequency of 30-day mortality with similar risk between groups: RFA 0%–0.7%; medical therapy 0%–4.2% (1/24).
Mortality <30 Days | Paroxysmal AF | 3 RCT (N=570) | Low | Low frequency of 30-day mortality with similar risk between groups: RFA 0%–0.7%; medical therapy 0%. One death occurred following a procedure-related cerebral stroke.
Mortality <30 Days | Persistent AF | 2 RCTs (N=191) | Low | Low frequency of 30-day mortality with similar risk between groups: RFA 0%; medical therapy 0%–4.2%. One sudden cardiac death occurred in a heart failure patient.
Mortality <30 Days | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Low 30-day mortality risk in both groups: RFA 0%; Medical therapy 0.4%. Definitive conclusions are not possible.^*^
Stroke <30 Days | All RCTs (regardless of AF type) | 8 RCTs (N=919) | Low | 30-day stroke risk following both treatments: RFA 0%–4.8%; medical therapy 0%.
Stroke <30 Days | Paroxysmal AF | 3 RCTs (N=481) | Low | Low frequency of 30-day stroke with similar risk between groups: RFA 0%–0.7%; medical therapy 0%. One procedure-related cerebral stroke occurred (and resulted in death).
Stroke <30 Days | Persistent AF | 3 RCTs (N=231) | Low | Low 30-day stroke risk following both treatments: RFA 0%–4.8%; medical therapy 0%. Both strokes occurred in patients with heart failure: one during the procedure and the other 6 days post-ablation.
Stroke <30 Days | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Higher 30-day stroke risk following RFA (2.6%) versus medical therapy (0.4%) (p=0.046). Definitive conclusions are not possible.^*^
Stroke <30 Days | Mixed | 2 RCTs (N=207); 1 comparative observational (N=166) | Low | Low 30-day stroke risk following both treatments: RFA 0%–1.5%; medical therapy 0%. One procedural stroke occurred. In the comparative observational study, 30-day stroke risk between groups: RFA 1.2%; medical therapy 1.2%.
AF <3 Months | Paroxysmal AF | 2 RCTs (N=183) | Low | No difference in 3-month AF risk between groups (pooled RR 0.67 [95% CI 0.40 to 1.10]).
AF <3 Months | Persistent AF | 2 RCTs (N=196) | Low | 2- to 3-month risk of AF lower following RFA versus medical therapy (pooled RR 0.18 [95% CI 0.11 to 0.30]).
Cardiac Tamponade^†^ | Paroxysmal AF | 4 RCTs (N=512); 1 comparative observational (N=85) | Low | The pooled cardiac tamponade risk following RFA was 1.7% (95% CI 0.8 to 3.6) based on data from four RCTs. The comparative observational study reported no cases of cardiac tamponade.
Cardiac Tamponade^†^ | Persistent AF | 3 RCTs (N=73) | Insufficient^*^ | The pooled cardiac tamponade risk following RFA was 5.5% (95% CI 2.1 to 13.7). Definitive conclusions are not possible.^*^
Cardiac Tamponade^†^ | Persistent AF: Medicare population | 1 comparative observational (N=158) | Insufficient^*^ | Cardiac tamponade occurred in 0% of patients. Definitive conclusions are not possible.^*^
Pericardial Effusion^†^ | All RCTs (regardless of AF type) | 5 RCTs (N=772) | Low | Low pericardial effusion risk following RFA (range, 0.5%–0.9%).
Pericardial Effusion^†^ | Paroxysmal AF | 3 RCTs (N=519) | Low | Low pericardial effusion risk following RFA (pooled risk 0.6% (95% CI 0.2 to 1.8).
Pericardial Effusion^†^ | Persistent AF | 1 RCT (N=116) | Insufficient^*^ | Low pericardial effusion risk following RFA (0.9%). Definitive conclusions are not possible.^*^
Pericardial Effusion^†^ | Persistent AF: Medicare population | 1 comparative observational (N=158) | Insufficient^*^ | Pericardial effusion occurred in 1.9% of patients. Definitive conclusions are not possible.^*^
Pericardial Effusion^†^ | Mixed | 1 RCT (N=137) | Low | Low pericardial effusion risk following RFA (0.7%).
Pulmonary Vein Stenosis^†^ | Paroxysmal AF | 5 RCTs (N=433) 1 comparative observational (N=85) | Low | Low pulmonary vein stenosis risk following RFA from five RCTs with followup ranging from 1–24 months (range, 0%–3.1%). Pooled risk based on two trials with 12-month followup: 1.6% (95% CI 0.4 to 6.3). Pooled risk based on two trials with 24-month followup: 0.7% (95% CI 0.2 to 2.8). No cases reported in the comparative observational study with 12 months followup.
Pulmonary Vein Stenosis^†^ | Persistent AF | 2 RCTs (N=137) | Low | Low pulmonary vein stenosis risk following RFA (range, 0%–0.9%). Pooled risk: 0.7% (95% CI 0.1 to 5.0).
Pulmonary Vein Stenosis^†^ | Persistent AF: Medicare population | 1 comparative observational (N=158) | Insufficient^*^ | There were no cases of pulmonary vein stenosis. Definitive conclusions are not possible.^*^
Pulmonary Vein Stenosis^†^ | Mixed | 1 RCT (N=137); 1 comparative observational (N=85) | Low | No cases of pulmonary vein stenosis following RFA based on the RCT. In the comparative observational study, stenosis occurred in 7.1% of patients. Definitive conclusions are not possible from this study.^*^
Drug Intolerance Requiring Discontinuation | Paroxysmal AF | 2 RCTs (N=155 medical therapy patients) | Low | Overall, 5% to 23% of patients randomized to medical therapy discontinued anti-arrhythmic drugs due to adverse events or intolerance; by 1 month in one trial, timing not reported in the second trial Due to limited duration and/or usage of medical therapy in the RFA group it is difficult to make comparative conclusions.
Drug Intolerance Requiring Discontinuation | Persistent AF: Medicare population | 1 comparative observational (N=412) | Insufficient^*^ | Lower risk of antiarrhythmic drug intolerance requiring discontinuation following RFA (2.6%) versus medical therapy (12.7%) (p=0.0005). Definitive conclusions are not possible.^*^
Drug Intolerance Requiring Discontinuation | Mixed | 1 RCT (N=70) | Insufficient^*^ | Low risk of antiarrhythmic drug intolerance requiring discontinuation following RFA and medical therapy (2.9% vs. 0%); timing not reported Definitive conclusions are not possible.

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

† Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.

Table G Key findings and strength of evidence for Key Question 2: Comparative short-term and long-term complications and harms associated with cryoballoon ablation versus medical therapy for AF

Harms/ Complications^*^ | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality <30 days | 1 RCT (N=245) | Insufficient^†^ | The 30-day all-cause mortality risk was 0% in both treatment groups. Definitive conclusions are not possible.^†^
Stroke <30 days | 1 RCT (N=245) | Insufficient^†^ | The 30-day stroke risk was low in both groups: cryoballoon ablation 0.6%; medical therapy 1.2%. Definitive conclusions are not possible.^†^
AF <3 months | 1 RCT (N=163) | Insufficient^†^ | Over half of cryoablation patients experienced AF recurrence within 3 months of treatment (51.5%); data was not reported for the medical therapy group. Definitive conclusions are not possible.^†^
Cardiac tamponade^‡^ | 1 RCT (N=228) | Insufficient^†^ | The incidence of cardiac tamponade following cryoballoon ablation was low (0.9%). Definitive conclusions are not possible.^†^
Pericardial effusion^‡^ | Not reported | Insufficient | No data available
Pulmonary vein stenosis^‡^ | 1 RCT (N=228) | Insufficient^†^ | The incidence of pulmonary vein stenosis following cryoballoon ablation was low (3.1%). Definitive conclusions are not possible.^†^
Drug intolerance requiring discontinuation | Not reported | Insufficient | No data available

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial.

* All harms/complications are for the same RCT in a mixed population (no other studies were identified for this comparison).

† Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

‡ Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.

Table H Key findings and strength of evidence for Key Question 2: Comparative short-term and long-term complications and harms associated with cryoballoon ablation versus RFA for AF

Harms/ complications | Population | Number of Studies (N) | Strength of Evidence Grade | Conclusions, Effect Size
Mortality <30 Days | Paroxysmal AF | 2 comparative observational (N=4171) | Insufficient^*^ | There were no cases reported in either group during the periprocedural period in two nonrandomized comparative studies. Definitive conclusions are not possible.^*^
Mortality <30 Days | Persistent AF, Mixed | Not reported | Insufficient | No data available
Stroke <30 Days | Paroxysmal AF | 1 comparative observational (N=133) | Insufficient^*^ | There were no cases reported in either group in one nonrandomized comparative study. Definitive conclusions are not possible.^*^
Stroke <30 Days | Persistent AF, Mixed | Not reported | Insufficient | No data available
AF <3 Months | Paroxysmal AF | 1 comparative observational (N=3775) | Insufficient^*^ | One nonrandomized comparative study reported similar AF recurrence rates in both groups during the hospitalization period. Definitive conclusions are not possible.^*^
AF <3 Months | Persistent AF, Mixed | Not reported | Insufficient | No data available
Cardiac Tamponade^†^ | Paroxysmal AF | 3 comparative observational (N=4304) | Insufficient^*^ | Periprocedural cardiac tamponade rates ranged from 0.7%–2.2% during cryoablation and from 1.1%–1.5% during RFA based on data from three nonrandomized comparative studies. Definitive conclusions are not possible.^*^
Cardiac Tamponade^†^ | Persistent AF, Mixed | Not reported | Insufficient | No data available
Pericardial Effusion^†^ | Paroxysmal AF | 2 comparative observational (N=529) | Insufficient^*^ | Pericardial effusion occurred in 7.3%–8.7% of cryoablation patients and in 10.0%–13.8% of RFA patients based on data from two nonrandomized comparative studies. Definitive conclusions are not possible.^*^
Pericardial Effusion^†^ | Persistent AF | Not reported | Insufficient | No data available
Pericardial Effusion^†^ | Mixed | 2 comparative observational (N=267) | Insufficient^*^ | Pericardial effusion occurred in 0%–1.1% of cryoablation patients and in 1.6%–3.8% of RFA patients based on data from two nonrandomized comparative studies. Definitive conclusions are not possible.^*^
Pulmonary Vein Stenosis^†^ | Paroxysmal AF | 2 comparative observational (N=4171) | Insufficient^*^ | There were no cases reported in either group during the periprocedural period in two nonrandomized comparative studies. Definitive conclusions are not possible.^*^
Pulmonary Vein Stenosis^†^ | Persistent AF | Not reported | Insufficient | No data available
Pulmonary Vein Stenosis^†^ | Mixed | 1 comparative observational (N=124) | Insufficient^*^ | There were no cases reported in either group during the periprocedural period in one nonrandomized comparative study. Definitive conclusions are not possible.^*^

AF = atrial fibrillation; KQ = Key Question; RCT = randomized controlled trial; RFA = radiofrequency ablation.

* Conclusions are not possible secondary to study limitations, small sample sizes or sparse data resulting in low precision of estimates, and/or unknown consistency from single studies.

† Ablation-related adverse events were reported for all patients who received ablation, either as randomized or who crossed over from the medical therapy group.

### Findings in Relationship to What is Already Known

Findings in this review were generally consistent with prior systematic reviews that included evaluation of catheter ablation versus medical therapy for AF.23, 25

This review expands information available from previous reviews in a number of ways. First, more recent publications comparing RFA with medical therapy with information on longer-term outcomes (>12 months) were included, as were studies comparing different energy sources. An attempt to specifically identify and summarize studies focused on the Medicare population was made. Based on input from Key Informants during Topic Refinement, analyses were stratified based on AF type (paroxysmal and persistent) when possible, as these are clinically different populations. Analyses to evaluate differential efficacy and harms for use of catheter ablation as a first-line treatment versus a second-line treatment, age, patient characteristics and comorbidities, provider characteristics and other factors were considered; however, data were too sparse to draw conclusions. This report also expands analyses of ablation-specific adverse events and includes a broader spectrum of outcomes such as reablation, echocardiographic parameters and biomarkers.

The two previous reviews yielded similar findings to the current review with respect to the benefit of RFA over medical therapy in improving freedom from recurrence of AF and/or maintenance of sinus rhythm.23, 25 The current review, however, extends the findings of both reviews report to include longer-term outcome data and a broader spectrum of endpoints, stratifying them by AF type. Similar to this current report, the Washington State Health Technology Assessment (HTA) in 2013 found low frequency of mortality or stroke not attributed to the procedure, with no differences between the ablation and medical therapy groups and there was low quality of evidence that there was no difference between RFA (or cyroablation) and medical therapy for the primary harms of interest.25 Both previous reports focused on the general population and reported a paucity of data in Medicare populations and for important clinical endpoints such as all-cause mortality, stroke, and heart failure, particularly in the long term.

Comparison of catheter ablation approaches/techniques to each other is an important question of interest to CMS but was beyond the scope of this review. There was substantial heterogeneity across included studies with respect to ablation techniques and sites that precluded their assessment in this review. Previous reviews provide some insight into this question. In the 2013 AHRQ review,22, 23, 25 information on the following aspects of the procedure was captured: type of ablation catheter used, whether cavotricuspid isthmus (CTI) ablation was performed in conjunction with the PVI, whether ablation of complex fractionated atrial electrograms (CFAEs) was done, and whether sites other than CTI and CFAEs were ablated. However, the data could not be pooled due to the insurmountable heterogeneity observed in different aspects of the procedure. RCTs that compared different approaches (i.e., PVI, wide area circumferential ablation [WACA], addition of right or left lines, CFAE) were included in the Washington State HTA.25 In terms of freedom from recurrence, there was low-quality evidence that WACA was favored over PVI, moderate-quality evidence that PVI plus CFE favored PVI alone, and moderate-quality evidence that there was no difference in recurrence following PVI versus PVI plus left lines or plus right lines. The HTA did not compare different ablation techniques.

### Applicability

The applicability of the findings from this review is described below.

#### Patients

The bulk of the available trial data were in populations predominantly male (59%–88%), with mean ages ranging from 51 to 64 years, and two observational studies provided only limited information in people ≥65 years of age. Based on information from Key Informants during the topic refinement process, primary clinical decisionmaking regarding use of ablation and ablation approach was based on type and characteristics of AF, presence and type of other cardiac disease, and patient presentation, rather than on any specific age consideration or characteristics specific to the Medicare population. Patients with AF may have had a number of comorbid conditions and other underlying cardiovascular problems. Three RCTs investigated outcomes in populations with comorbidities often seen in conjunction with AF: two were conducted specifically in patients with heart failure (all with persistent AF)37, 38 and one in patients with type 2 diabetes mellitus.35 Mean left ventricular ejection fractions across studies that did not focus on heart failure were greater than 50 percent. Comorbidities were variably reported across the other RCTs. Hypertension was the most commonly reported comorbidity, with proportions ranging from 11 to 56 percent across studies. A number of subgroups of potential interest were identified by the Key Informants. However, there were insufficient data from included studies to evaluate the benefits and harms of catheter ablation in any subgroup. The evidence presented in this review may not apply to older people or to those with a greater number of comorbidities or more severe comorbidities (e.g., heart failure).

#### Interventions

A wide variety of ablation strategies were used across studies. Based on input from Key Informants there is substantial variability in techniques and approaches used in clinical practice as well. Heterogeneity across studies with respect to techniques used precluded evaluation or comparison of specific techniques (and such evaluation was beyond the scope of this report). Findings from one small study comparing cryoballoon ablation to medical therapy may not be applicable to the broader population of AF patients eligible for catheter ablation. This is also true for the studies comparing energy sources.

#### Comparators

The primary antiarrhythmic medications used in studies included amiodarone, sotalol, flecainide, and propafenone. Amiodarone is the most commonly used antiarrhythmic in clinical practice, but the others are also used. Antiarrhythmic agents used in the included studies were considered to be reflective of clinical practice and applicable to broad clinical populations with AF.

#### Outcomes

Findings related to rare outcomes may not be fully applicable to broader clinical populations in part due to small study sizes and inability to fully characterize such outcomes. The nature of the comorbidities and study settings of the study populations may have also influenced findings and may differ from broader clinical populations. “Freedom from recurrence” is a complex concept and there is no clear consensus in the medical community on how best to measure it and no standard of care for monitoring it. Definitions varied across trials with some counting any atrial arrhythmia, whether symptomatic or asymptomatic, as recurrence, while others specified symptomology, duration, and characteristics. The heterogeneity in definition and measurement of recurrence makes it challenging to fully evaluate freedom from recurrence as a benefit of catheter ablation.

#### Settings

RCTs were primarily conducted in academically-oriented centers. Input from Key Informants suggested that there is great variability in practice in the clinical community. Findings from studies based in high volume centers with highly experienced providers may not be applicable to smaller centers and/or less experienced providers. Observational studies may be more reflective of the range of experience across settings. Both effectiveness and adverse events may differ by setting; however, there were insufficient data to evaluate this.

### Implications for Clinical and Policy Decisionmaking

RFA is increasingly being used to treat AF. The bulk of the available evidence compared RFA with medical therapy and in patients with paroxysmal AF. Evidence in this report provided insights that may be useful for clinical and policy decisionmaking on use of RFA compared with medical therapy to treat patients with paroxysmal AF and persistent AF as distinct clinical populations and on use of RFA as a first or second-line treatment. Evidence for shorter-term and longer-term efficacy, effectiveness, and safety is also valuable to decisionmaking. For clinical outcomes, there was insufficient evidence for the use of cryoballoon ablation compared with either medical therapy or RFA to support evidence-based decisionmaking in the general population and no evidence for these comparisons in the Medicare population.

#### Medicare Population

Neither of the included comparative observational studies provided data for patients with paroxysmal AF for either short- or long-term effectiveness precluding evidence-based conclusions for this AF type in the Medicare population. One study was in patients with persistent AF55 and the other in patients with various AF types,54 although approximately 70 percent were classified by the authors as having “nonparoxysmal” without further description. No data on short-term outcomes were available and for all long-term outcomes, evidence was considered insufficient. RFA was used as second-line treatment in both studies, thus no evidence on the benefits or harms of RFA as a first-line therapy in the Medicare population was available to support evidence-based decisionmaking. Conflicting findings across the two studies with regard to long-term mortality and development of CHF may be attributable to difference in comorbidities, study execution, and confounding control. Only the study in those with persistent AF provided data that long-term maintenance of sinus rhythm occurred more frequently following RFA (58%) compared with those remaining on medical therapy (43%).55 Definitive conclusions regarding effectiveness are not possible based on the evidence available. Similarly, insufficient evidence on harms of RFA compared with medical therapy precluded drawing evidence-based conclusions in the Medicare population.

#### General Population

In the general population, evidence on the long-term efficacy of RFA compared with medical therapy for reducing mortality was low for paroxysmal AF. Data on the other primary outcomes of stroke, MI, and heart failure were sparse for patients with paroxysmal AF, and no long-term RCT data for any of these outcomes were found for those with persistent AF. Data on quality of life were not conclusive as results could not be pooled from studies due to substantial heterogeneity. In patients with persistent AF and concomitant heart failure, three small studies suggested better HRQOL following RFA compared with medical therapy at 6 months. For intermediate outcomes, moderate-strength evidence indicated that for patients with either paroxysmal AF or persistent AF, radiofrequency ablation is effective in the short term (≤12 months) for preventing recurrence of atrial arrhythmias compared with medical therapy. While this appeared to be sustained over a longer term in patients with paroxysmal AF, there is insufficient evidence for this in patients with persistent AF. Thus, evidence-based decisionmaking regarding the long-term efficacy for those with persistent AF is limited.

Overall, hospitalization was more frequent in those who received medical therapy versus RFA, however studies did not provide detail regarding reasons for hospitalization and the extent to which hospitalization for reablation procedures or crossover from medical therapy to ablation were included.

This review found very limited evidence from one study that compared cryoballoon ablation with medical therapy and included patients with different AF types. Two small RCTs comparing cryoballoon ablation with RFA provided no data on primary outcomes of interest and neither reported on adverse events. Freedom from recurrence was less common following cryoballoon ablation and reablation was more common, but sample sizes may have precluded observation of statistical differences between treatments. There was limited evidence comparing cryoballoon ablation with other treatment options (including RFA) to inform policy or decisionmaking regarding the balance of benefits and risks based on current evidence.

In general, guidelines and consensus statements from professional societies such as the American College of Cardiology (ACC), American Heart Association (AHA), and Heart Rhythm Society (HRS) recommend catheter ablation for symptomatic AF that is refractory or intolerant to antiarrhythmic medication(s), however the specifics and strength of the recommendations vary by guideline.18, 19, 66, 67 68 Current ACC/AHA/HRS guidelines recommend that AF catheter ablation: is useful for symptomatic paroxysmal AF refractory or intolerant to at least one antiarrhythmic medication (Class I); is reasonable for some patients with symptomatic persistent AF refractory or intolerant to at least one antiarrhythmic medication (Class IIa); is reasonable as an initial rhythm-control strategy before drug therapy in patients with recurrent symptomatic paroxysmal AF (Class IIa); may be considered for symptomatic long-standing persistent AF refractory or intolerant to at least one antiarrhythmic medication (Class IIb); and may be considered in patients with symptomatic persistent AF (Class IIb). They further recommend that AF catheter ablation should not be performed in patients who cannot be treated with anticoagulant therapy with the sole intent of obviating the need for anticoagulation (Class III).5 Evidence in our report suggested that effect sizes for freedom from recurrence are not different when RFA is used as a first-line treatment or as a second-line treatment, but there was insufficient evidence to draw conclusions regarding how RFA as a first-line treatment versus a second-line treatment may influence a broader range of outcomes or for the longer term, and no evidence on this in the Medicare population.

### Limitations of the Review Process

The findings presented have limitations related to the approach and scope of this review. First, comparative evaluation of ablation techniques and approaches was beyond the scope of this review. There was substantial heterogeneity across included studies with regard to techniques and approaches that precluded comparative evaluation of studies. Though evaluation of mapping modalities and strategies was also beyond the scope of this review, we found insufficient information from included studies to assess mapping.

Stratification by AF type was felt to be clinically important and stratification to assess data at followup at >12 months was important to answering Key Questions. This resulted in fewer studies available for pooling within followup strata. Profile likelihood methods were used to provide more conservative estimates and confidence intervals given the small number of studies. This, combined with sparse data for many outcomes, may have limited the ability to explore statistical heterogeneity and precluded ability for further subgroup analyses.

Non-English studies were excluded and searches for studies published only as abstracts were not conducted. Formal assessment of publication bias was not conducted as there were fewer than 10 studies available for outcomes based on AF type, and research indicates that such methods can be misleading with smaller numbers of studies.69

Every attempt was made to assure that variables and outcomes were assessed and abstracted accurately, however wide variability across studies (in the quality of reporting of study methods, in how outcomes were defined, and in which patients were included) has the potential for introducing inaccuracies.

### Limitations of the Evidence Base

Important limitations of the evidence base include the sample size of the available trials, limited data available on primary clinical outcomes particularly at followup times >12 months, and the substantial crossover from medical therapy to catheter ablation in most trials. These factors made it difficult to draw strong conclusions regarding the effects and benefits of catheter ablation. Only one RCT comparing cryoballoon ablation with medical therapy was identified, and two small trials comparing cryoballoon ablation with RFA were identified but didn’t provide data on primary outcomes of interest. This precludes drawing conclusions regarding the comparative effectiveness of various energy sources.

The evidence base was constrained by the methodological limitations of the included studies. Common methodological shortcomings included unclear allocation concealment (only one trial documented concealed allocation) and lack of assessor blinding for primary outcomes. Four studies did not report information on random sequence generation.36, 39, 41, 47

Although not a factor for determination of individual study quality or overall strength of evidence, the high frequency of crossover from medical therapy to ablation in most included studies may have hindered drawing definitive conclusions regarding the full benefits and harms of catheter ablation compared with medical therapy.

Study sizes were likely insufficient to effectively determine risk of the primary clinical outcomes (e.g., mortality) for either group or to detect statistical differences between treatment groups. Two recent large observational studies that reported on the primary outcomes of interest in this report were identified but were excluded as there was insufficient information on use of anti-arrhythmic drugs versus rate control medications or no treatment in the control groups.70, 71 Both studies suggest that risk of stroke was significantly lower in patients receiving catheter ablation for AF compared with those who did not receive ablation in followup to 3.5 years. One study, based on administrative data from a large regional registry, stratified stroke risk by CHADS2 score and age reported that reduced stroke risk was present in all age groups and across all CHADS2 risk profiles.70 The other study based on Taiwan’s National Health Insurance claims database, reported that there was no association between RFA and lower mortality or hospitalization for heart failure.71 Although both studies attempted to control for confounding, the possibility of residual confounding from unmeasured factors should be considered as should the limitations of administrative data (such as misclassification) when interpreting these findings.72 Findings should be confirmed in additional high-quality studies that provide specifics regarding treatments received.

A variety of HRQOL measures were used at varied time frames across trials; this, along with small sample sizes, limited the ability to pool data or draw firm conclusions regarding the impact of catheter ablation on HRQOL, as discussed previously.

For the freedom from recurrence outcome, the definitions used by each study were accepted. This outcome was variably defined across studies, with variations in the type of arrhythmia (i.e., AF, AF or atrial flutter, or any atrial arrhythmia) and whether study reports were limited to symptomatic or asymptomatic AF or not. Maintenance of sinus rhythm appeared to be used interchangeably with freedom from recurrence in many studies, although these two outcomes are not the same.

Most studies focused on the intermediate outcome related to freedom from recurrence. This was variably defined and adjudicated across studies; there was heterogeneity across studies regarding whether recurrence included any atrial arrhythmia or AF only, whether symptomatic and asymptomatic recurrences were included, and whether characteristics related to duration were considered. In addition, blanking periods ranged from 1 to 3 months across 11 RCTs. This variability in study protocols likely introduces variation in the cross-study calculations of the proportion of those free from AF after the blanking period.

There was less evidence on the effectiveness of catheter ablation in patients with persistent AF and limited evidence on use of catheter ablation as a first-line treatment, limiting the conclusions that can be drawn in these instances. No data were available to assess the differential efficacy and harms of catheter ablation by patient or provider characteristics.

### Research Gaps

Gaps in evidence were identified for each Key Question.

Key Question 1: RFA or cryoablation versus medical therapy and comparison of cryoablation versus RFA

- There was limited data on the impact of RFA compared with medical therapy on final clinical outcomes such as mortality, particularly in the long term. Long-term data was particularly sparse for those with persistent AF.
- Data was sparse for the comparison of cryoballoon ablation versus medical therapy and for the comparison of cryoballoon ablation with RFA for all clinically-relevant outcomes.
- No data from high-quality comparative studies on Medicare-relevant populations were identified.
- Across studies, there was lack of a standardized, consistent method of measuring, monitoring, and reporting “freedom from recurrence” or maintenance is sinus rhythm.
- Conclusions related to HRQOL and symptom relief were not possible from the included studies due the variety of HRQOL measures reported across different time frames and inconsistency in statistical significance.
- Ideally future studies would conceptualize strategies for treatment of AF, such as catheter ablation and medical therapy, and evaluate the impact of such strategies on hard clinical outcome such as death and stroke.

Key Question 2: Harms

- Comparative data on rare harms were limited by study sample sizes particularly in those with persistent AF. This was true for the comparisons of RFA versus medical therapy as well as for the comparisons of cryoballoon ablation with medical therapy or RFA.

Key Question 3: Differential efficacy, effectiveness, harms

- Available RCTs did not have sufficient power to evaluate differential efficacy or harm of catheter ablation (RFA or cryoballoon ablation) verses medical therapy or for comparison of cryoballoon ablation with RFA for specific patient subgroups or provider settings. No conclusions are possible regarding which patients may benefit most or regarding which patients may not benefit from catheter ablation with current evidence.
- Limited data on use of RFA as the first treatment of choice (first-line therapy) versus a second-line therapy following failure of antiarrhythmic medications were available. No data for cryoballoon ablation were available to evaluate its use as first versus second-line therapy.

Some of these gaps may be addressed via the CABANA Trial (https://www.cabanatrial.org/), which is scheduled for completion in March 2018. This RCT conceptualizes ablation and medical therapy as strategies for treatment of AF and compares first-line ablation with pharmacologic therapy for reducing the composite endpoint of total mortality, disabling stroke, serious bleeding, or cardiac arrest in patients with atrial fibrillation. The target sample size is 2200 and current enrollment is about 1650 patients across 126 study sites in 10 countries. The trial will likely have good representation of Medicare patients, as to be eligible for the trial, patients must be either 65 years of age or older or have at least one risk factor for stroke. In addition, inclusion of patients with specific risk factors for stroke (e.g. hypertension, diabetes) may facilitate better understanding of the impact of catheter ablation in subpopulations with specific risk factors. One potential limitation of the trial includes the use of a composite outcome as the primary outcome measure, which may preclude adequate characterization and representation of important individual outcomes. This may limit conclusions which can be drawn regarding the efficacy of catheter ablation versus medical therapy to affect clinical outcomes such as mortality, stroke, and development of CHF if there is insufficient power to evaluate these as separate outcomes although they are listed as intermediate outcomes for this study. Another limitation is its span over a very long period of time (started in 2009) during which technology is evolving quickly. Thus, equipment and techniques that were used earlier in the trial may not be relevant to clinical practice when the trial ends. It is not clear if there will be sufficient data to evaluate efficacy separately by AF type or to compare ablation techniques. The planned followup of approximately 5 years will provide additional evidence on the longer-term impact of catheter ablation on clinical outcomes. Results from CABANA will enhance the current evidence base and provide much needed information on efficacy and safety particularly in those >65 years of age. In addition to CABANA, several other trials are currently evaluating aspects of catheter ablation for the treatment of AF, including a total of 14 relevant ongoing clinical trials were identified using the United States National Institute of Health clinical registry (www.ClinicalTrials.gov) (Appendix, Table H8).

In addition to the evidence the CABANA trial and other currently open trials may yield, there is a need to evaluate effectiveness across clinical settings and provider skill levels outside of randomized trials. There are several key elements that might augment the productivity of future research. For example, high-quality clinical registries, designed a priori to address specific clinical questions, could provide an important source for addressing some research gaps. Such registries could be designed to extend the observations from randomized trials; this approach might differ from currently available study results by allowing for evaluation of the durability of the effects seen with longer followup, including a larger sample size to examine rare events, and including a broader range of patients to facilitate evaluation of how well patient groups are represented in clinical trials. Specific components that could be considered for capture include: more detailed information on patient and provider characteristics; AF details (duration, prior treatments, and episode severity); procedural details (e.g., mapping, catheter use, and technique/approach); management of patients before, during, and after procedure; and acute procedural outcomes as well as longer-term outcomes and complications. Such a registry could be used to address important issues such as how outcomes in clinical practice compare with outcomes observed in clinical trials and how outcomes are associated with characteristics of patients and providers. Registries could help determine performance measures and assist with quality improvement, post-marketing safety public reporting as well. There are, however, a number of limitations and factors to consider for registries. A challenge of creating and maintaining a registry is the potential difficulty of balancing the burden of high-quality data collection with acceptable registry size. Designing a large registry can be more costly but not necessarily more valuable than a registry of smaller size or other study types. Registries designed to test specific medical devices face logistical problems including variability in insurance coverage for specific devices, influence of operator characteristics while using the same device, and difficulty in differentially identifying unique devices in use. An additional challenge of maintaining a registry is that research questions may change after data collection begins which causes a shift in the importance of some of the data elements collected.73 Registry studies would not replace the need for high-quality comparative studies. Pragmatic trials and comparative observational studies that are designed to reduce bias may facilitate evaluation of effectiveness and safety in the “real world” and over the long term in particular. Such studies could provide a foundation for registry development. Methodologically rigorous prospective cohort studies comparing treatments based on standardized protocols can potentially provide high-quality data. Such studies might be complemented with data from registries.

There may be some value in performing meta-analysis on individual patient data from relevant clinical trials to more effectively stratify outcomes by patient characteristics, comorbidities, and factors such as use of catheter ablation as an initial first-line treatment versus a second-line treatment. The small sample sizes of individual trials may, however, limit such exploration.

In order to evaluate the extent to which there is differential efficacy or harm for specific subpopulations, clinical trials need to have sufficient statistical power to stratify by important groups and to test for statistical interaction. Future studies, regardless of design, would benefit from the use of standardized definitions and methods of measuring salient outcomes (e.g., freedom from recurrence)and detailed reporting of cointerventions that may influence outcomes (e.g., use of antiarrhythmic medications in ablation groups and use of anticoagulation).

The technologies and strategies related to catheter ablation (and mapping) continues to evolve. Information on newer technologies including phased radiofrequency ablation (phased RFA), laser balloon ablation, contact force-guided radiofrequency (CF-guided RFA), and mesh ablation is emerging in the peer-reviewed literature. Present literature indicates they may be effective alternatives to currently available technologies, however additional evidence is needed to verify early findings.74–79

Future systematic reviews will need to include technologies as they are approved and become widely available as well as updated studies of newer technologies such as cryoballoon ablation that are already approved but have a limited evidence base. Given the rapid evolution of catheter ablation, it will be important to update reviews such as this in the near future.

## Conclusions

Evidence was insufficient to draw conclusions on the efficacy, effectiveness, and harms of catheter ablation for AF specific to the Medicare population. In the general population, conclusions regarding the long-term efficacy of catheter ablation to impact primary clinical outcomes were limited; in those with paroxysmal AF, strength of evidence is low that there is no difference between RFA and medical therapy in all-cause-mortality. Low strength of evidence means that there is limited confidence that the effect estimate is close to the true effect. Evidence from RCTs was insufficient for no differences in stroke, MI and CHF after 12 months. Although observational studies may suggest lower stroke and heart failure risk following RFA versus medical therapy, the evidence was insufficient. In the short term, strength of evidence was low that there were no differences between treatments for all-cause mortality and MI and insufficient for stroke and CHF, regardless of AF type. No overall conclusions could be drawn regarding the impact of RFA on HRQOL across studies. In patients with heart failure and persistent AF, low strength of evidence suggested quality of life may be improved following RFA up to 6 months. No long-term RCT data in those with persistent AF for the primary outcomes of mortality, stroke, MI, or development of CHF were identified. For intermediate outcomes, moderate strength of evidence indicated that RFA is superior to medical therapy for enhancing patient freedom from recurrence of atrial arrhythmias in the short term in those with paroxysmal AF and appears to be sustained for the longer term. Strength of evidence was low for freedom from recurrence in those with persistent AF in the short term and insufficient in the longer term. Regarding harms, there was low strength of evidence for no difference between RFA and medical therapy in 30-day mortality or 30-day stroke. There was low strength of evidence that there was no difference between RFA and medical therapy in 3-month risk of AF in paroxysmal AF patients, but data from two trials of persistent AF patients suggested significantly lower risk of 2- to 3-month AF recurrence following RFA versus medical therapy (low strength of evidence). Risk estimates for cardiac tamponade following RFA were imprecise; the strength of evidence was low regardless of AF type. There is insufficient evidence comparing cryoballoon ablation with medical therapy for outcomes other than freedom from protocol defined treatment failure which favored cryoballoon ablation. There was insufficient evidence comparing cryoballoon ablation versus RFA to draw conclusions regarding efficacy or safety.

In summary, there was insufficient evidence to draw conclusions regarding the efficacy, effectiveness and safety of catheter ablation in the Medicare population. In the general population, there was moderate evidence that RFA is superior to medical therapy for enhancing patient freedom from recurrence of atrial arrhythmias in both the short- and long- term regardless of AF type, but reablation is common. RFA does not appear to impact all-cause mortality in the short or long term in those with paroxysmal AF (low strength of evidence), however there was insufficient evidence to draw conclusions regarding other primary clinical outcomes in the short or long term. Firm conclusions regarding HRQOL are not possible given heterogeneity across studies for instruments employed, measurement timing, and clinical characteristics. For harms, no differences between RFA and medical therapy in 30-day mortality, stroke, or 3-month risk of AF were seen (low strength of evidence). Evidence comparing cryoballoon ablation with medical therapy or with RFA was insufficient to draw conclusions regarding efficacy or safety, with the exception of low strength of evidence for greater freedom from protocol-defined failure following cryoballoon ablation versus medical therapy. To better understand the impact of catheter ablation on key outcomes (stroke, mortality, quality of life, and symptom improvement) compared to other treatment strategies, large methodologically sound studies are needed, particularly on persistent AF patients. Studies with sufficient sample sizes are needed to effectively determine whether catheter ablation versus other treatments will benefit certain patient subgroups more than others, and whether there are subgroups in which catheter ablation might best used as a first- versus second-line treatment.

### References

1 Go AS, Hylek EM, Phillips KA, et al. Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. May. 9. 2001;285(18):2370-2375. [pmid: 11343485].
2 Magnani JW, Rienstra M, Lin H, et al. Atrial fibrillation: current knowledge and future directions in epidemiology and genomics. Circulation. Nov. 1. 2011;124(18):1982-1993. [pmid: 22042927].
3 Kannel WB, Benjamin EJ. Status of the epidemiology of atrial fibrillation. The Medical clinics of North America. Jan. 2008;92(1):17-40. ix. [pmid: 18060995].
4 Sause A, Tutdibi O, Pomsel K, et al. Limiting esophageal temperature in radiofrequency ablation of left atrial tachyarrhythmias results in low incidence of thermal esophageal lesions. BMC cardiovascular disorders. 2010;10:52. [pmid: 20977747].
5 January CT, Wann LS, Alpert JS, et al. 2014 AHA/ACC/HRS Guideline for the Management of Patients With Atrial Fibrillation: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. Dec. 2. 2014;64(21):2246-2280.
6 Furberg CD, Psaty BM, Manolio TA, et al. Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). American Journal of Cardiology. Aug. 1. 1994;74(3):236-241. [pmid: 8037127].
7 Schotten U, Verheule S, Kirchhof P, et al. Pathophysiological mechanisms of atrial fibrillation: a translational appraisal. Physiological reviews. Jan. 2011;91(1):265-325. [pmid: 21248168].
8 Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. Aug. 1991;22(8):983-988. [pmid: 1866765].
9 Lin HJ, Wolf PA, Kelly-Hayes M, et al. Stroke severity in atrial fibrillation. The Framingham Study. Stroke. Oct. 1996;27(10):1760-1764. [pmid: 8841325].
10 Krahn AD, Manfreda J, Tate RB, et al. The natural history of atrial fibrillation: incidence, risk factors, and prognosis in the Manitoba Follow-Up Study. American Journal of Medicine. May. 1995;98(5):476-484. [pmid: 7733127].
11 Poole-Wilson PA, Swedberg K, Cleland JG, et al. Comparison of carvedilol and metoprolol on clinical outcomes in patients with chronic heart failure in the Carvedilol Or Metoprolol European Trial (COMET): randomised controlled trial. Lancet. Jul. 5. 2003;362(9377):7-13. [pmid: 12853193].
12 Maggioni AP, Latini R, Carson PE, et al. Valsartan reduces the incidence of atrial fibrillation in patients with heart failure: results from the Valsartan Heart Failure Trial (Val-HeFT). American Heart Journal. Mar. 2005;149(3):548-557. [pmid: 15864246].
13 Wang TJ, Larson MG, Levy D, et al. Temporal relations of atrial fibrillation and congestive heart failure and their joint influence on mortality: the Framingham Heart Study. Circulation. Jun. 17. 2003;107(23):2920-2925. [pmid: 12771006].
14 Singh SN, Tang XC, Singh BN, et al. Quality of life and exercise performance in patients in sinus rhythm versus persistent atrial fibrillation: a Veterans Affairs Cooperative Studies Program Substudy. Journal of the American College of Cardiology. Aug. 15. 2006;48(4):721-730. [pmid: 16904540].
15 Dorian P, Jung W, Newman D, et al. The impairment of health-related quality of life in patients with intermittent atrial fibrillation: implications for the assessment of investigational therapy. Journal of the American College of Cardiology. Oct. 2000;36(4):1303-1309. [pmid: 11028487].
16 Chung MK, Shemanski L, Sherman DG, et al. Functional status in rate-versus rhythm-control strategies for atrial fibrillation: results of the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) Functional Status Substudy. Journal of the American College of Cardiology. Nov. 15. 2005;46(10):1891-1899. [pmid: 16286177].
17 Hagens VE, Ranchor AV, Van Sonderen E, et al. Effect of rate or rhythm control on quality of life in persistent atrial fibrillation. Results from the Rate Control Versus Electrical Cardioversion (RACE) Study. Journal of the American College of Cardiology. Jan. 21. 2004;43(2):241-247. [pmid: 14736444].
18 Fuster V, Ryden LE, Cannom DS, et al. 2011 ACCF/AHA/HRS focused updates incorporated into the ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: a report of the American College of Cardiology Foundation/American Heart Association Task Force on practice guidelines. Circulation. Mar. 15. 2011;123(10):e269-e367. [pmid: 21382897].
19 Calkins H, Kuck KH, Cappato R, et al. 2012 HRS/EHRA/ECAS expert consensus statement on catheter and surgical ablation of atrial fibrillation: recommendations for patient selection, procedural techniques, patient management and follow-up, definitions, endpoints, and research trial design: a report of the Heart Rhythm Society (HRS) Task Force on Catheter and Surgical Ablation of Atrial Fibrillation. Developed in partnership with the European Heart Rhythm Association (EHRA), a registered branch of the European Society of Cardiology (ESC) and the European Cardiac Arrhythmia Society (ECAS); and in collaboration with the American College of Cardiology (ACC), American Heart Association (AHA), the Asia Pacific Heart Rhythm Society (APHRS), and the Society of Thoracic Surgeons (STS). Endorsed by the governing bodies of the American College of Cardiology Foundation, the American Heart Association, the European Cardiac Arrhythmia Society, the European Heart Rhythm Association, the Society of Thoracic Surgeons, the Asia Pacific Heart Rhythm Society, and the Heart Rhythm Society. Heart Rhythm. Apr. 2012;9(4):632-696 e21. [pmid: 22386883].
20 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: full text: a report of the American College of Cardiology/American Heart Association Task Force on practice guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 guidelines for the management of patients with atrial fibrillation) developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Europace. Sep. 2006;8(9):651-745. [pmid: 16987906].
21 Wann LS, Curtis AB, January CT, et al. 2011 ACCF/AHA/HRS focused update on the management of patients with atrial fibrillation (updating the 2006 guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. Circulation. Jan. 4. 2011;123(1):104-123. [pmid: 21173346].
22 Ip S, Terasawa T, Balk EM, et al. Comparative Effectiveness of Radiofrequency Catheter Ablation for Atrial Fibrillation. AHRQ Comparative Effectiveness Reviews. Rockville (MD). Agency for Healthcare Research and Quality (US). 2009.
23 Al-Khatib SM, Allen Lapointe N, Chatterjee R, et al. Treatment of Atrial Fibrillation. AHRQ Comparative Effectiveness Reviews, No. 119. Rockville (MD). Agency for Healthcare Research and Quality (US). 2013.
24 Chen HS, Wen JM, Wu SN, et al. Catheter ablation for paroxysmal and persistent atrial fibrillation. Cochrane Database Syst Rev. 2012;4:CD007101. [pmid: 22513945].
25 Hashimoto RE, Raich AL, Junge M, et al. Catheter ablation procedures for supraventricular tachyarrhythmia (SVTA) including atrial flutter and atrial fibrillation. Olympia, WA. Washington State Health Care Authority, Health Technology Assessment Program. 2103. www.hta.hca.wa.gov/svta.html.
26 Ellis ER, Culler SD, Simon AW, et al. Trends in utilization and complications of catheter ablation for atrial fibrillation in Medicare beneficiaries. Heart Rhythm. Sep. 2009;6(9):1267-1273. [pmid: 19716081].
27 Cappato R, Calkins H, Chen SA, et al. Updated worldwide survey on the methods, efficacy, and safety of catheter ablation for human atrial fibrillation. Circ Arrhythm Electrophysiol. Feb. 2010;3(1):32-38. [pmid: 19995881].
28 Agency for Healthcare Research and Quality. Methods guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov. Accessed July 30, 2014.
29 Higgins JPT GS, editor. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. ed. 2011.
30 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
31 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Statistics in medicine. Mar. 30. 1996;15(6):619-629. [pmid: 8731004].
32 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ (Clinical research ed.). Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
33 Fu R, Vandermeer BW, Shamliyan TA, et al. AHRQ Methods for Effective Health CareHandling Continuous Outcomes in Quantitative Synthesis. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville MD. Agency for Healthcare Research and Quality (US). 2008.
34 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-1207. [pmid: 21463926].
35 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):22-28. [pmid: 18775050].
36 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study.[Erratum appears in Circulation. 2009 Sep 8;120(10):e83]. Circulation. Dec. 9. 2008;118(24):2498-2505. [pmid: 19029470].
37 Jones DG, Haldar SK, Hussain W, et al. A randomized trial to assess catheter ablation versus rate control in the management of persistent atrial fibrillation in heart failure. Journal of the American College of Cardiology. 2013;61(18):1894-1903. NEW. [pmid: 23500267].
38 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. May. 2011;97(9):740-747. [pmid: 21051458].
39 Mont L, Bisbal F, Hernandez-Madrid A, et al. Catheter ablation vs. antiarrhythmic drug treatment of persistent atrial fibrillation: a multicentre, randomized, controlled trial (SARA study). European heart journal. 2013. Oct. 17. [pmid: 24135832].
40 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. Mar. 2. 2006;354(9):934-941. [pmid: 16510747].
41 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. Journal of the American College of Cardiology. Dec. 5. 2006;48(11):2340-2347. [pmid: 17161267].
42 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). European heart journal. Jan. 2006;27(2):216-221. [pmid: 16214831].
43 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. Jun. 1. 2005;293(21):2634-2640. [pmid: 15928285].
44 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. Jan. 27. 2010;303(4):333-340. [pmid: 20103757].
45 Cosedis Nielsen J, Johannessen A, Raatikainen P, et al. Radiofrequency ablation as initial therapy in paroxysmal atrial fibrillation. N Engl J Med. Oct. 25. 2012;367(17):1587-1595. [pmid: 23094720].
46 Morillo CA, Verma A, Connolly SJ, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation (RAAFT-2): a randomized trial. JAMA. Feb. 19. 2014;311(7):692-700. [pmid: 24549549].
47 Pappone C, Vicedomini G, Augello G, et al. Radiofrequency catheter ablation and antiarrhythmic drug therapy: a prospective, randomized, 4-year follow-up trial: the APAF study. Circ. Dec. 2011;4(6):808-814. [pmid: 21946315].
48 Hunter RJ, Berriman TJ, Diab I, et al. A randomized controlled trial of catheter ablation versus medical treatment of atrial fibrillation in heart failure (the CAMTAF trial). Circ Arrhythm Electrophysiol. Feb. 2014;7(1):31-38. [pmid: 24382410].
49 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. Nov. 2010;3(6):615-623. [pmid: 20940250].
50 Lan X, Su L, Ling Z, et al. Catheter ablation vs. amiodarone plus losartan for prevention of atrial fibrillation recurrence in patients with paroxysmal atrial fibrillation. Eur J Clin Invest. Aug. 2009;39(8):657-663. [pmid: 19490069].
51 Sang C-H, Chen K, Pang X-F, et al. Depression, anxiety, and quality of life after catheter ablation in patients with paroxysmal atrial fibrillation. Clin Cardiol. Jan. 2013;36(1):40-45. [pmid: 22777577].
52 Yu S, Zhao Q, Wu P, et al. Effect of anxiety and depression on the recurrence of paroxysmal atrial fibrillation after circumferential pulmonary vein ablation. Journal of Cardiovascular Electrophysiology. Nov. Suppl 1. 2012;23:S17-S23. [pmid: 22998234].
53 Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. J Cardiovasc Med (Hagerstown). Jan. 2008;9(1):51-55. [pmid: 18268419].
54 Sonne K, Patel D, Mohanty P, et al. Pulmonary vein antrum isolation, atrioventricular junction ablation, and antiarrhythmic drugs combined with direct current cardioversion: survival rates at 7 years follow-up. J Interv Card Electrophysiol. Nov. 2009;26(2):121-126. [pmid: 19789970].
55 Blandino A, Toso E, Scaglione M, et al. Long-term efficacy and safety of two different rhythm control strategies in elderly patients with symptomatic persistent atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jul. 2013;24(7):731-738. [pmid: 23551460].
56 Reynolds MR, Gunnarsson CL, Hunter TD, et al. Health outcomes with catheter ablation or antiarrhythmic drug therapy in atrial fibrillation: results of a propensity-matched analysis. Circ Cardiovasc Qual Outcomes. Mar. 1. 2012;5(2):171-181. [pmid: 22373904].
57 Packer DL, Kowal RC, Wheelan KR, et al. Cryoballoon ablation of pulmonary veins for paroxysmal atrial fibrillation: first results of the North American Arctic Front (STOP AF) pivotal trial. Journal of the American College of Cardiology. Apr. 23. 2013;61(16):1713-1723. [pmid: 23500312].
58 Perez-Castellano N, Fernandez-Cavazos R, Moreno J, et al. The COR trial: a randomized study with continuous rhythm monitoring to compare the efficacy of cryoenergy and radiofrequency for pulmonary vein isolation. Heart Rhythm. Jan. 2014;11(1):8-14. [pmid: 24103221].
59 Herrera Siklody C, Deneke T, Hocini M, et al. Incidence of asymptomatic intracranial embolic events after pulmonary vein isolation: comparison of different atrial fibrillation ablation technologies in a multicenter study. Journal of the American College of Cardiology. Aug. 9. 2011;58(7):681-688. [pmid: 21664090].
60 Chierchia GB, Capulzini L, Droogmans S, et al. Pericardial effusion in atrial fibrillation ablation: a comparison between cryoballoon and radiofrequency pulmonary vein isolation. Europace. Mar. 2010;12(3):337-341. [pmid: 20056597].
61 Knecht S, Sticherling C, von Felten S, et al. Long-term comparison of cryoballoon and radiofrequency ablation of paroxysmal atrial fibrillation: a propensity score matched analysis. Int J Cardiol. Oct. 20. 2014;176(3):645-650. [pmid: 25149399].
62 Kojodjojo P, O'Neill MD, Lim PB, et al. Pulmonary venous isolation by antral ablation with a large cryoballoon for treatment of paroxysmal and persistent atrial fibrillation: medium-term outcomes and non-randomised comparison with pulmonary venous isolation by radiofrequency ablation. Heart. Sep. 2010;96(17):1379-1384. [pmid: 20801856].
63 Mandell J, Amico F, Parekh S, et al. Early experience with the cryoablation balloon procedure for the treatment of atrial fibrillation by an experienced radiofrequency catheter ablation center. J Invasive Cardiol. Jun. 2013;25(6):288-292. [pmid: 23735354].
64 Mugnai G, Chierchia GB, de Asmundis C, et al. Comparison of pulmonary vein isolation using cryoballoon versus conventional radiofrequency for paroxysmal atrial fibrillation. The American journal of cardiology. May. 1. 2014;113(9):1509-1513. [pmid: 24630388].
65 Schmidt M, Dorwarth U, Andresen D, et al. Cryoballoon versus RF ablation in paroxysmal atrial fibrillation: results from the German Ablation Registry. J Cardiovasc Electrophysiol. Jan. 2014;25(1):1-7. [pmid: 24134539].
66 Bertaglia E, Fassini G, Anselmino M, et al. Comparison of ThermoCool Surround Flow catheter versus ThermoCool catheter in achieving persistent electrical isolation of pulmonary veins: a pilot study. Journal of Cardiovascular Electrophysiology. Mar. 2013;24(3):269-273. [pmid: 23210452].
67 Verma A, Macle L, Cox J, et al. Canadian Cardiovascular Society atrial fibrillation guidelines 2010: catheter ablation for atrial fibrillation/atrial flutter. Can J Cardiol. Jan-Feb. 2011;27(1):60-66. [pmid: 21329863].
68 Camm AJ, Kirchhof P, Lip GYH, et al. Guidelines for the management of atrial fibrillation. European heart journal. 2010;31.
69 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ (Clinical research ed.). 2011;343:d4002. [pmid: 21784880].
70 Bunch TJ, May HT, Bair TL, et al. Atrial fibrillation ablation patients have long-term stroke rates similar to patients without atrial fibrillation regardless of CHADS2 score. Heart Rhythm. Sep. 2013;10(9):1272-1277. [pmid: 23835257].
71 Chang CH, Lin JW, Chiu FC, et al. Effect of radiofrequency catheter ablation for atrial fibrillation on morbidity and mortality: a nationwide cohort study and propensity score analysis. Circ. Feb. 2014;7(1):76-82.
72 Hashimoto RE, Brodt ED, Skelly AC, et al. Administrative database studies: goldmine or goose chase?. Evidence-based spine-care journal. Oct. 2014;5(2):74-76. [pmid: 25278880].
73 AHRQ Methods for Effective Health Care. Gliklich RE, Dreyer NA, Leavy MB, editors. Registries for Evaluating Patient Outcomes: A User's Guide. Rockville (MD). Agency for Healthcare Research and Quality (US). 2014.
74 Malmborg H, Lonnerholm S, Blomstrom P, et al. Ablation of atrial fibrillation with cryoballoon or duty-cycled radiofrequency pulmonary vein ablation catheter: a randomized controlled study comparing the clinical outcome and safety; the AF-COR study. Europace. Nov. 2013;15(11):1567-1573. [pmid: 23703361].
75 Malmborg H, Christersson C, Lonnerholm S, et al. Comparison of effects on coagulation and inflammatory markers using a duty-cycled bipolar and unipolar radiofrequency pulmonary vein ablation catheter vs. a cryoballoon catheter for pulmonary vein isolation. Europace. Jun. 2013;15(6):798-804. [pmid: 23362019].
76 Hummel J, Michaud G, Hoyt R, et al. Phased RF ablation in persistent atrial fibrillation. Heart Rhythm. Feb. 2014;11(2):202-209. [pmid: 24239841].
77 Bordignon S, Chun KR, Gunawardene M, et al. Comparison of balloon catheter ablation technologies for pulmonary vein isolation: the laser versus cryo study. Journal of Cardiovascular Electrophysiology. Sep. 2013;24(9):987-994. [pmid: 23800359].
78 Jourda F, Providencia R, Marijon E, et al. Contact-force guided radiofrequency vs. second-generation balloon cryotherapy for pulmonary vein isolation in patients with paroxysmal atrial fibrillation-a prospective evaluation. Europace. 2014. Sep. 3. [pmid: 25186456].
79 Koch L, Haeusler KG, Herm J, et al. Mesh ablator vs. cryoballoon pulmonary vein ablation of symptomatic paroxysmal atrial fibrillation: results of the MACPAF study. Europace. Oct. 2012;14(10):1441-1449. [pmid: 22523379].