# References

1 Go AS, Hylek EM, Phillips KA, et al. Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. May. 9. 2001;285(18):2370-2375. [pmid: 11343485].
2 Magnani JW, Rienstra M, Lin H, et al. Atrial fibrillation: current knowledge and future directions in epidemiology and genomics. Circulation. Nov. 1. 2011;124(18):1982-1993. [pmid: 22042927].
3 Kannel WB, Benjamin EJ. Status of the epidemiology of atrial fibrillation. The Medical clinics of North America. Jan. 2008;92(1):17-40. ix. [pmid: 18060995].
4 January CT, Wann LS, Alpert JS, et al. 2014 AHA/ACC/HRS Guideline for the Management of Patients With Atrial Fibrillation: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. Dec. 2. 2014;64(21):2246-2280.
5 Furberg CD, Psaty BM, Manolio TA, et al. Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). American Journal of Cardiology. Aug. 1. 1994;74(3):236-241. [pmid: 8037127].
6 Schotten U, Verheule S, Kirchhof P, et al. Pathophysiological mechanisms of atrial fibrillation: a translational appraisal. Physiological reviews. Jan. 2011;91(1):265-325. [pmid: 21248168].
7 Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. Aug. 1991;22(8):983-988. [pmid: 1866765].
8 Lin HJ, Wolf PA, Kelly-Hayes M, et al. Stroke severity in atrial fibrillation. The Framingham Study. Stroke. Oct. 1996;27(10):1760-1764. [pmid: 8841325].
9 Krahn AD, Manfreda J, Tate RB, et al. The natural history of atrial fibrillation: incidence, risk factors, and prognosis in the Manitoba Follow-Up Study. American Journal of Medicine. May. 1995;98(5):476-484. [pmid: 7733127].
10 Poole-Wilson PA, Swedberg K, Cleland JG, et al. Comparison of carvedilol and metoprolol on clinical outcomes in patients with chronic heart failure in the Carvedilol Or Metoprolol European Trial (COMET): randomised controlled trial. Lancet. Jul. 5. 2003;362(9377):7-13. [pmid: 12853193].
11 Maggioni AP, Latini R, Carson PE, et al. Valsartan reduces the incidence of atrial fibrillation in patients with heart failure: results from the Valsartan Heart Failure Trial (Val-HeFT). American Heart Journal. Mar. 2005;149(3):548-557. [pmid: 15864246].
12 Wang TJ, Larson MG, Levy D, et al. Temporal relations of atrial fibrillation and congestive heart failure and their joint influence on mortality: the Framingham Heart Study. Circulation. Jun. 17. 2003;107(23):2920-2925. [pmid: 12771006].
13 Singh SN, Tang XC, Singh BN, et al. Quality of life and exercise performance in patients in sinus rhythm versus persistent atrial fibrillation: a Veterans Affairs Cooperative Studies Program Substudy. Journal of the American College of Cardiology. Aug. 15. 2006;48(4):721-730. [pmid: 16904540].
14 Dorian P, Jung W, Newman D, et al. The impairment of health-related quality of life in patients with intermittent atrial fibrillation: implications for the assessment of investigational therapy. Journal of the American College of Cardiology. Oct. 2000;36(4):1303-1309. [pmid: 11028487].
15 Chung MK, Shemanski L, Sherman DG, et al. Functional status in rate-versus rhythm-control strategies for atrial fibrillation: results of the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) Functional Status Substudy. Journal of the American College of Cardiology. Nov. 15. 2005;46(10):1891-1899. [pmid: 16286177].
16 Hagens VE, Ranchor AV, Van Sonderen E, et al. Effect of rate or rhythm control on quality of life in persistent atrial fibrillation. Results from the Rate Control Versus Electrical Cardioversion (RACE) Study. Journal of the American College of Cardiology. Jan. 21. 2004;43(2):241-247. [pmid: 14736444].
17 Fuster V, Ryden LE, Cannom DS, et al. 2011 ACCF/AHA/HRS focused updates incorporated into the ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: a report of the American College of Cardiology Foundation/American Heart Association Task Force on practice guidelines. Circulation. Mar. 15. 2011;123(10):e269-e367. [pmid: 21382897].
18 Calkins H, Kuck KH, Cappato R, et al. 2012 HRS/EHRA/ECAS expert consensus statement on catheter and surgical ablation of atrial fibrillation: recommendations for patient selection, procedural techniques, patient management and follow-up, definitions, endpoints, and research trial design: a report of the Heart Rhythm Society (HRS) Task Force on Catheter and Surgical Ablation of Atrial Fibrillation. Developed in partnership with the European Heart Rhythm Association (EHRA), a registered branch of the European Society of Cardiology (ESC) and the European Cardiac Arrhythmia Society (ECAS); and in collaboration with the American College of Cardiology (ACC), American Heart Association (AHA), the Asia Pacific Heart Rhythm Society (APHRS), and the Society of Thoracic Surgeons (STS). Endorsed by the governing bodies of the American College of Cardiology Foundation, the American Heart Association, the European Cardiac Arrhythmia Society, the European Heart Rhythm Association, the Society of Thoracic Surgeons, the Asia Pacific Heart Rhythm Society, and the Heart Rhythm Society. Heart Rhythm. Apr. 2012;9(4):632-696 e21. [pmid: 22386883].
19 Fuster V, Ryden LE, Cannom DS, et al. ACC/AHA/ESC 2006 guidelines for the management of patients with atrial fibrillation: full text: a report of the American College of Cardiology/American Heart Association Task Force on practice guidelines and the European Society of Cardiology Committee for Practice Guidelines (Writing Committee to Revise the 2001 guidelines for the management of patients with atrial fibrillation) developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Europace. Sep. 2006;8(9):651-745. [pmid: 16987906].
20 Wann LS, Curtis AB, January CT, et al. 2011 ACCF/AHA/HRS focused update on the management of patients with atrial fibrillation (updating the 2006 guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. Circulation. Jan. 4. 2011;123(1):104-123. [pmid: 21173346].
21 Ip S, Terasawa T, Balk EM, et al. Comparative Effectiveness of Radiofrequency Catheter Ablation for Atrial Fibrillation. AHRQ Comparative Effectiveness Reviews. Rockville (MD). Agency for Healthcare Research and Quality (US). 2009.
22 Al-Khatib SM, Allen Lapointe N, Chatterjee R, et al. Treatment of Atrial Fibrillation. AHRQ Comparative Effectiveness Reviews, No. 119. Rockville (MD). Agency for Healthcare Research and Quality (US). 2013.
23 Chen HS, Wen JM, Wu SN, et al. Catheter ablation for paroxysmal and persistent atrial fibrillation. Cochrane Database Syst Rev. 2012;4:CD007101. [pmid: 22513945].
24 Hashimoto RE, Raich AL, Junge M, et al. Catheter ablation procedures for supraventricular tachyarrhythmia (SVTA) including atrial flutter and atrial fibrillation. Olympia, WA. Washington State Health Care Authority, Health Technology Assessment Program. 2103. www.hta.hca.wa.gov/svta.html.
25 Ellis ER, Culler SD, Simon AW, et al. Trends in utilization and complications of catheter ablation for atrial fibrillation in Medicare beneficiaries. Heart Rhythm. Sep. 2009;6(9):1267-1273. [pmid: 19716081].
26 Cappato R, Calkins H, Chen SA, et al. Updated worldwide survey on the methods, efficacy, and safety of catheter ablation for human atrial fibrillation. Circ Arrhythm Electrophysiol. Feb. 2010;3(1):32-38. [pmid: 19995881].
27 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. International journal of surgery (London, England). 2010;8(5):336-341. [pmid: 20171303].
28 Agency for Healthcare Research and Quality. Methods guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov. Accessed July 30, 2014.
29 Higgins JPT GS, editor. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. ed. 2011.
30 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-523. [pmid: 19595577].
31 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Statistics in medicine. Mar. 30. 1996;15(6):619-629. [pmid: 8731004].
32 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ (Clinical research ed.). Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
33 Fu R, Vandermeer BW, Shamliyan TA, et al. AHRQ Methods for Effective Health Care Handling Continuous Outcomes in Quantitative Synthesis. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). Agency for Healthcare Research and Quality (US). 2008.
34 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-1207. [pmid: 21463926].
35 Cosedis Nielsen J, Johannessen A, Raatikainen P, et al. Radiofrequency ablation as initial therapy in paroxysmal atrial fibrillation. N Engl J Med. Oct. 25. 2012;367(17):1587-1595. [pmid: 23094720].
36 Forleo GB, Mantica M, De Luca L, et al. Catheter ablation of atrial fibrillation in patients with diabetes mellitus type 2: results from a randomized study comparing pulmonary vein isolation versus antiarrhythmic drug therapy. Journal of Cardiovascular Electrophysiology. Jan. 2009;20(1):22-28. [pmid: 18775050].
37 Hunter RJ, Berriman TJ, Diab I, et al. A randomized controlled trial of catheter ablation versus medical treatment of atrial fibrillation in heart failure (the CAMTAF trial). Circ Arrhythm Electrophysiol. Feb. 2014;7(1):31-38. [pmid: 24382410].
38 Jais P, Cauchemez B, Macle L, et al. Catheter ablation versus antiarrhythmic drugs for atrial fibrillation: the A4 study.[Erratum appears in Circulation. 2009 Sep 8; 120(10):e83]. Circulation. Dec. 9. 2008;118(24):2498-2505. [pmid: 19029470].
39 Jones DG, Haldar SK, Hussain W, et al. A randomized trial to assess catheter ablation versus rate control in the management of persistent atrial fibrillation in heart failure. Journal of the American College of Cardiology. 2013;61(18):1894-1903. CN-00907192 NEW. [pmid: 23500267].
40 MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: a randomised controlled trial. Heart. May. 2011;97(9):740-747. [pmid: 21051458].
41 Mont L, Bisbal F, Hernandez-Madrid A, et al. Catheter ablation vs. antiarrhythmic drug treatment of persistent atrial fibrillation: a multicentre, randomized, controlled trial (SARA study). European heart journal. 2013. Oct. 17. [pmid: 24135832].
42 Morillo CA, Verma A, Connolly SJ, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of paroxysmal atrial fibrillation (RAAFT-2): a randomized trial. JAMA. Feb. 19. 2014;311(7):692-700. [pmid: 24549549].
43 Oral H, Pappone C, Chugh A, et al. Circumferential pulmonary-vein ablation for chronic atrial fibrillation. N Engl J Med. Mar. 2. 2006;354(9):934-941. [pmid: 16510747].
44 Pappone C, Augello G, Sala S, et al. A randomized trial of circumferential pulmonary vein ablation versus antiarrhythmic drug therapy in paroxysmal atrial fibrillation: the APAF Study. Journal of the American College of Cardiology. Dec. 5. 2006;48(11):2340-2347. [pmid: 17161267].
45 Stabile G, Bertaglia E, Senatore G, et al. Catheter ablation treatment in patients with drug-refractory atrial fibrillation: a prospective, multi-centre, randomized, controlled study (Catheter Ablation For The Cure Of Atrial Fibrillation Study). European heart journal. Jan. 2006;27(2):216-221. [pmid: 16214831].
46 Wazni OM, Marrouche NF, Martin DO, et al. Radiofrequency ablation vs antiarrhythmic drugs as first-line treatment of symptomatic atrial fibrillation: a randomized trial. JAMA. Jun. 1. 2005;293(21):2634-2640. [pmid: 15928285].
47 Wilber DJ, Pappone C, Neuzil P, et al. Comparison of antiarrhythmic drug therapy and radiofrequency catheter ablation in patients with paroxysmal atrial fibrillation: a randomized controlled trial. JAMA. Jan. 27. 2010;303(4):333-340. [pmid: 20103757].
48 Blandino A, Toso E, Scaglione M, et al. Long-term efficacy and safety of two different rhythm control strategies in elderly patients with symptomatic persistent atrial fibrillation. Journal of Cardiovascular Electrophysiology. Jul. 2013;24(7):731-738. [pmid: 23551460].
49 Lan X, Su L, Ling Z, et al. Catheter ablation vs. amiodarone plus losartan for prevention of atrial fibrillation recurrence in patients with paroxysmal atrial fibrillation. Eur J Clin Invest. Aug. 2009;39(8):657-663. [pmid: 19490069].
50 Reynolds MR, Gunnarsson CL, Hunter TD, et al. Health outcomes with catheter ablation or antiarrhythmic drug therapy in atrial fibrillation: results of a propensity-matched analysis. Circ Cardiovasc Qual Outcomes. Mar. 1. 2012;5(2):171-181. [pmid: 22373904].
51 Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. J Cardiovasc Med (Hagerstown). Jan. 2008;9(1):51-55. [pmid: 18268419].
52 Sang C-H, Chen K, Pang X-F, et al. Depression, anxiety, and quality of life after catheter ablation in patients with paroxysmal atrial fibrillation. Clin Cardiol. Jan. 2013;36(1):40-45. [pmid: 22777577].
53 Sonne K, Patel D, Mohanty P, et al. Pulmonary vein antrum isolation, atrioventricular junction ablation, and antiarrhythmic drugs combined with direct current cardioversion: survival rates at 7 years follow-up. J Interv Card Electrophysiol. Nov. 2009;26(2):121-126. [pmid: 19789970].
54 Yu S, Zhao Q, Wu P, et al. Effect of anxiety and depression on the recurrence of paroxysmal atrial fibrillation after circumferential pulmonary vein ablation. Journal of Cardiovascular Electrophysiology. Nov. Suppl 1. 2012;23:S17-S23. [pmid: 22998234].
55 Bertaglia E, Zoppo F, Tondo C, et al. Early complications of pulmonary vein catheter ablation for atrial fibrillation: a multicenter prospective registry on procedural safety. Heart Rhythm. Oct. 2007;4(10):1265-1271. [pmid: 17905330].
56 Bunch TJ, Crandall BG, Weiss JP, et al. Patients treated with catheter ablation for atrial fibrillation have long-term rates of death, stroke, and dementia similar to patients without atrial fibrillation. Journal of Cardiovascular Electrophysiology. Aug. 2011;22(8):839-845. [pmid: 21410581].
57 Dagres N, Hindricks G, Kottkamp H, et al. Complications of atrial fibrillation ablation in a high-volume center in 1,000 procedures: still cause for concern?. Journal of Cardiovascular Electrophysiology. Sep. 2009;20(9):1014-1019. [pmid: 19490383].
58 Gibson DN, Di Biase L, Mohanty P, et al. Stiff left atrial syndrome after catheter ablation for atrial fibrillation: clinical characterization, prevalence, and predictors.[Erratum appears in Heart Rhythm. 2011 Nov;8(11):1828]. Heart Rhythm. Sep. 2011;8(9):1364-1371. [pmid: 21354332].
59 Hoyt H, Bhonsale A, Chilukuri K, et al. Complications arising from catheter ablation of atrial fibrillation: temporal trends and predictors. Heart Rhythm. Dec. 2011;8(12):1869-1874. [pmid: 21798230].
60 Hunter RJ, McCready J, Diab I, et al. Maintenance of sinus rhythm with an ablation strategy in patients with atrial fibrillation is associated with a lower risk of stroke and death. Heart. Jan. 2012;98(1):48-53. [pmid: 21930724].
61 Shah RU, Freeman JV, Shilane D, et al. Procedural complications, rehospitalizations, and repeat procedures after catheter ablation for atrial fibrillation. J Am Coll Cardiol. Jan. 10. 2012;59(2):143-149. [pmid: 22222078].
62 Deshmukh A, Patel NJ, Pant S, et al. In-hospital complications associated with catheter ablation of atrial fibrillation in the United States between 2000 and 2010: analysis of 93 801 procedures. Circulation. 2013;128(19):2104-2112. [pmid: 24061087].
63 Sacher F, Monahan KH, Thomas SP, et al. Phrenic nerve injury after atrial fibrillation catheter ablation: characterization and outcome in a multicenter study. J Am Coll Cardiol. Jun. 20. 2006;47(12):2498-2503. [pmid: 16781380].
64 Baman TS, Jongnarangsin K, Chugh A, et al. Prevalence and predictors of complications of radiofrequency catheter ablation for atrial fibrillation. Journal of Cardiovascular Electrophysiology. 2011;22(6):626-631. [pmid: 21235674].
65 Piccini JP, Sinner MF, Greiner MA, et al. Outcomes of Medicare beneficiaries undergoing catheter ablation for atrial fibrillation. Circulation. Oct. 30. 2012;126(18):2200-2207. [pmid: 23019293].
66 D'Ascenzo F, Corleto A, Biondi-Zoccai G, et al. Which are the most reliable predictors of recurrence of atrial fibrillation after transcatheter ablation?: a meta-analysis. International Journal of Cardiology. Sep. 1. 2013;167(5):1984-1989. [pmid: 22626840].
67 Hao SC, Hunter TD, Gunnarsson C, et al. Acute safety outcomes in younger and older patients with atrial fibrillation treated with catheter ablation. J Interv Card Electrophysiol. Nov. 2012;35(2):173-182. [pmid: 22714547].
68 Kosiuk J, Kornej J, Bollmann A, et al. Early cerebral thromboembolic complications after radiofrequency catheter ablation of atrial fibrillation: Incidence, characteristics, and risk factors. Heart Rhythm. Nov. 2014;11(11):1934-1940. [pmid: 25086257].
69 Michowitz Y, Rahkovich M, Oral H, et al. Effects of sex on the incidence of cardiac tamponade after catheter ablation of atrial fibrillation: results from a worldwide survey in 34 943 atrial fibrillation ablation procedures. Circ Arrhythm Electrophysiol. Apr. 2014;7(2):274-280. [pmid: 24519888].
70 Srivatsa UN, Danielsen B, Anderson I, et al. Risk predictors of stroke and mortality after ablation for atrial fibrillation: The California experience 2005–2009. Heart Rhythm. Nov. 2014;11(11):1898-1903. [pmid: 25048442].
71 Zado E, Callans DJ, Riley M, et al. Long-term clinical efficacy and risk of catheter ablation for atrial fibrillation in the elderly. J Cardiovasc Electrophysiol. Jun. 2008;19(6):621-626. [pmid: 18462325].
72 Packer DL, Irwin JM, Champagne J. Cryoballoon ablation of pulmonary veins for paroxysmal atrial fibrillation: first results of the North American Arctic Front STOP-AF pivotal trial. J Am Coll Cardiol. 2010;55:E3015-E3016.
73 Andrade JG, Khairy P, Macle L, et al. Incidence and significance of early recurrences of atrial fibrillation after cryoballoon ablation: insights from the multicenter Sustained Treatment of Paroxysmal Atrial Fibrillation (STOP AF) Trial. Circ Arrhythm Electrophysiol. Feb. 2014;7(1):69-75. [pmid: 24446022].
74 Herrera Siklody C, Deneke T, Hocini M, et al. Incidence of asymptomatic intracranial embolic events after pulmonary vein isolation: comparison of different atrial fibrillation ablation technologies in a multicenter study. Journal of the American College of Cardiology. Aug. 9. 2011;58(7):681-688. [pmid: 21664090].
75 Perez-Castellano N, Fernandez-Cavazos R, Moreno J, et al. The COR trial: a randomized study with continuous rhythm monitoring to compare the efficacy of cryoenergy and radiofrequency for pulmonary vein isolation. Heart Rhythm. Jan. 2014;11(1):8-14. [pmid: 24103221].
76 Chierchia GB, Capulzini L, Droogmans S, et al. Pericardial effusion in atrial fibrillation ablation: a comparison between cryoballoon and radiofrequency pulmonary vein isolation. Europace. Mar. 2010;12(3):337-341. [pmid: 20056597].
77 Knecht S, Sticherling C, von Felten S, et al. Long-term comparison of cryoballoon and radiofrequency ablation of paroxysmal atrial fibrillation: a propensity score matched analysis. Int J Cardiol. Oct. 20. 2014;176(3):645-650. [pmid: 25149399].
78 Kojodjojo P, O'Neill MD, Lim PB, et al. Pulmonary venous isolation by antral ablation with a large cryoballoon for treatment of paroxysmal and persistent atrial fibrillation: medium-term outcomes and non-randomised comparison with pulmonary venous isolation by radiofrequency ablation. Heart. Sep. 2010;96(17):1379-1384. [pmid: 20801856].
79 Mandell J, Amico F, Parekh S, et al. Early experience with the cryoablation balloon procedure for the treatment of atrial fibrillation by an experienced radiofrequency catheter ablation center. J Invasive Cardiol. Jun. 2013;25(6):288-292. [pmid: 23735354].
80 Mugnai G, Chierchia GB, de Asmundis C, et al. Comparison of pulmonary vein isolation using cryoballoon versus conventional radiofrequency for paroxysmal atrial fibrillation. The American journal of cardiology. May. 1. 2014;113(9):1509-1513. [pmid: 24630388].
81 Schmidt M, Dorwarth U, Andresen D, et al. Cryoballoon versus RF ablation in paroxysmal atrial fibrillation: results from the German Ablation Registry. J Cardiovasc Electrophysiol. Jan. 2014;25(1):1-7. [pmid: 24134539].
82 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. J Clin Epidemiol. Oct. 2009;62(10):e1-e34. [pmid: 19631507].
83 Pappone C, Vicedomini G, Augello G, et al. Radiofrequency catheter ablation and antiarrhythmic drug therapy: a prospective, randomized, 4-year follow-up trial: the APAF study. Circ. Dec. 2011;4(6):808-814. [pmid: 21946315].
84 Reynolds MR, Walczak J, White SA, et al. Improvements in symptoms and quality of life in patients with paroxysmal atrial fibrillation treated with radiofrequency catheter ablation versus antiarrhythmic drugs. Circ Cardiovasc Qual Outcomes. Nov. 2010;3(6):615-623. [pmid: 20940250].
85 Wynn GJ, Das M, Bonnett LJ, et al. Quality-of-life benefits of catheter ablation of persistent atrial fibrillation: a reanalysis of data from the SARA study. Europace. 2014. Jul. 15. [pmid: 25028177].
86 Packer DL, Kowal RC, Wheelan KR, et al. Cryoballoon ablation of pulmonary veins for paroxysmal atrial fibrillation: first results of the North American Arctic Front (STOP AF) pivotal trial. Journal of the American College of Cardiology. Apr. 23. 2013;61(16):1713-1723. [pmid: 23500312].
87 Sanders GD, Hlatky MA, Owens DK. Cost-effectiveness of implantable cardioverter-defibrillators. The New England journal of medicine. Oct. 6. 2005;353(14):1471-1480. [pmid: 16207849].
88 Koch L, Haeusler KG, Herm J, et al. Mesh ablator vs. cryoballoon pulmonary vein ablation of symptomatic paroxysmal atrial fibrillation: results of the MACPAF study. Europace. Oct. 2012;14(10):1441-1449. [pmid: 22523379].
89 Malmborg H, Christersson C, Lonnerholm S, et al. Comparison of effects on coagulation and inflammatory markers using a duty-cycled bipolar and unipolar radiofrequency pulmonary vein ablation catheter vs. a cryoballoon catheter for pulmonary vein isolation. Europace. Jun. 2013;15(6):798-804. [pmid: 23362019].
90 Bertaglia E, Fassini G, Anselmino M, et al. Comparison of ThermoCool Surround Flow catheter versus ThermoCool catheter in achieving persistent electrical isolation of pulmonary veins: a pilot study. Journal of Cardiovascular Electrophysiology. Mar. 2013;24(3):269-273. [pmid: 23210452].
91 Verma A, Macle L, Cox J, et al. Canadian Cardiovascular Society atrial fibrillation guidelines 2010: catheter ablation for atrial fibrillation/atrial flutter. Can J Cardiol. Jan-Feb. 2011;27(1):60-66. [pmid: 21329863].
92 Camm AJ, Kirchhof P, Lip GYH, et al. Guidelines for the management of atrial fibrillation. European heart journal. 2010;31.
93 January CT, Wann LS, Alpert JS, et al. 2014 AHA/ACC/HRS Guideline for the Management of Patients With Atrial Fibrillation: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2014. Mar. 28. [pmid: 24685669].
94 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ (Clinical research ed.). 2011;343:d4002. [pmid: 21784880].
95 Bunch TJ, May HT, Bair TL, et al. Atrial fibrillation ablation patients have long-term stroke rates similar to patients without atrial fibrillation regardless of CHADS2 score. Heart Rhythm. Sep. 2013;10(9):1272-1277. [pmid: 23835257].
96 Chang CH, Lin JW, Chiu FC, et al. Effect of radiofrequency catheter ablation for atrial fibrillation on morbidity and mortality: a nationwide cohort study and propensity score analysis. Circ. Feb. 2014;7(1):76-82.
97 Hashimoto RE, Brodt ED, Skelly AC, et al. Administrative database studies: goldmine or goose chase?. Evidence-based spine-care journal. Oct. 2014;5(2):74-76. [pmid: 25278880].
98 AHRQ Methods for Effective Health Care. Gliklich RE, Dreyer NA, Leavy MB, editors. Registries for Evaluating Patient Outcomes: A User's Guide. Rockville (MD). Agency for Healthcare Research and Quality (US). 2014.
99 Malmborg H, Lonnerholm S, Blomstrom P, et al. Ablation of atrial fibrillation with cryoballoon or duty-cycled radiofrequency pulmonary vein ablation catheter: a randomized controlled study comparing the clinical outcome and safety; the AF-COR study. Europace. Nov. 2013;15(11):1567-1573. [pmid: 23703361].
100 Hummel J, Michaud G, Hoyt R, et al. Phased RF ablation in persistent atrial fibrillation. Heart Rhythm. Feb. 2014;11(2):202-209. [pmid: 24239841].
101 Bordignon S, Chun KR, Gunawardene M, et al. Comparison of balloon catheter ablation technologies for pulmonary vein isolation: the laser versus cryo study. Journal of Cardiovascular Electrophysiology. Sep. 2013;24(9):987-994. [pmid: 23800359].
102 Jourda F, Providencia R, Marijon E, et al. Contact-force guided radiofrequency vs. second-generation balloon cryotherapy for pulmonary vein isolation in patients with paroxysmal atrial fibrillation-a prospective evaluation. Europace. 2014. Sep. 3. [pmid: 25186456].