# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kim Wittenberg, M.A., Task Order Officer (TOO). We also thank Elaine Graham, M.L.S. for Program guidance and collaborative support; Tracy Dana, M.L.S. for assistance with the literature search; Leah Williams, B.S. for editorial assistance; Katie Moran, B.S. and Kathryn Mihalovich, B.S. for assistance with data abstraction; and Katie Moran, B.S. for assistance with project management.