# Appendices

APPENDIX A Search Strategy

APPENDIX B List of Included Studies

APPENDIX C List of Excluded Studies with Rationale

APPENDIX D Sample Data Extraction Forms

APPENDIX E Evidence Tables

APPENDIX F Quality Assessment of Included Studies

APPENDIX G Strength of Evidence Tables

APPENDIX H Description of Outcomes Measures, Devices, and Ongoing Trials, and Additional Results Tables