# REFERENCES

## Included Studies

Arnaiz E, Jelic V, Almkvist O, et al. Impaired cerebral glucose metabolism and cognitive functioning predict deterioration in mild cognitive impairment. Neuroreport. 2001;12(4):851-855. [pmid: 11277595].
Block W, Traber F, Flacke S, et al. In-vivo proton MR-spectroscopy of the human brain: assessment of N-acetylaspartate (NAA) reduction as a marker for neurodegeneration. Amino Acids. 2002;23(1–3):317-323. [pmid: 12373553].
Bohnen NI, Kaufer DI, Ivanco LS, et al. Cortical cholinergic function is more severely affected in parkinsonian dementia than in Alzheimer disease: an in vivo positron emission tomographic study. Archives of Neurology. 2003;60(12):1745-1748. [pmid: 14676050].
Bookheimer SY, Strojwas MH, Cohen MS, et al. Patterns of brain activation in people at risk for Alzheimer's disease.[see comment]. New England Journal of Medicine. 2000;343(7):450-456. [pmid: 10944562].
Charpentier P, Lavenu I, Defebvre L, et al. Alzheimer's disease and frontotemporal dementia are differentiated by discriminant analysis applied to (99m)Tc HmPAO SPECT data. Journal of Neurology, Neurosurgery & Psychiatry. 2000;69(5):661-663.
Chetelat G, Desgranges B, de la Sayette V, et al. Mild cognitive impairment: Can FDG-PET predict who is to rapidly convert to Alzheimer's disease?. Neurology. 2003;60(8):1374-1377. [pmid: 12707450].
de Leon MJ, Convit A, Wolf OT, et al. Prediction of cognitive decline in normal elderly subjects with 2-[(18)F]fluoro-2-deoxy-D-glucose/poitron-emission tomography (FDG/PET). Proceedings of the National Academy of Sciences of the United States of America. 2001;98(19):10966-10971. [pmid: 11526211].
Defebvre LJ, Leduc V, Duhamel A, et al. Technetium HMPAO SPECT study in dementia with Lewy bodies, Alzheimer's disease and idiopathic Parkinson's disease. Journal of Nuclear Medicine. 1999;40(6):956-962. [pmid: 10452310].
Dickerson BC, Goncharova I, Sullivan MP, et al. MRI-derived entorhinal and hippocampal atrophy in incipient and very mild Alzheimer's disease. Neurobiology of Aging. 2001;22(5):747-754. [pmid: 11705634].
Doraiswamy PM, Charles HC, Krishnan KR. Prediction of cognitive decline in early Alzheimer's disease. Lancet. 1998;352(9141):1678. [pmid: 9853445].
Fox NC, Crum WR, Scahill RI, et al. Imaging of onset and progression of Alzheimer's disease with voxel-compression mapping of serial magnetic resonance images. Lancet. 2001;358(9277):201-205. [pmid: 11476837].
Grundman M, Sencakova D, Jack CR Jr, et al. Brain MRI hippocampal volume and prediction of clinical status in a mild cognitive impairment trial. Journal of Molecular Neuroscience. 2002;19(1–2):23-27. [pmid: 12212787].
Jack CR Jr, Petersen RC, Xu YC, et al. Rates of hippocampal atrophy correlate with change in clinical status in aging and AD. Neurology. 2000;55(4):484-489. [pmid: 10953178].
Jack CR Jr, Petersen RC, Xu YC, et al. Prediction of AD with MRI-based hippocampal volume in mild cognitive impairment. Neurology. 1999;52(7):1397-1403. [pmid: 10227624].
Jack CR Jr, Shiung MM, Gunter BL, et al. Comparison of different MRI brain atrophy rate measures with clinical disease progression in AD. Neurology. 2004;62:591-600. [pmid: 14981176].
Jessen F, Block W, Traber F, et al. Decrease of N-acetylaspartate in the MTL correlates with cognitive decline of AD patients. Neurology. 2001;57(5):930-932. [pmid: 11552037].
Jobst KA, Barnetson LP, Shepstone BJ. Accurate prediction of histologically confirmed Alzheimer's disease and the differential diagnosis of dementia: the use of NINCDS-ADRDA and DSM-III-R criteria, SPECT, X-ray CT, and Apo E4 in medial temporal lobe dementias. Oxford Project to Investigate Memory and Aging.[republished from Int Psychogeriatr. 1997;9 Suppl 1:191–222; discussion 247–52; PMID: 9447442]. International Psychogeriatrics. 1998;10(3):271-302. [pmid: 9785148].
Johnson KA, Lopera F, Jones K, et al. Presenilin-1-associated abnormalities in regional cerebral perfusion. Neurology. 2001;56(11):1545-1551. [pmid: 11402113].
Kantarci K, Jack CR Jr, Xu YC, et al. Mild cognitive impairment and Alzheimer disease: regional diffusivity of water. Radiology. 2001;219(1):101-107. [pmid: 11274543].
Killiany RJ, Gomez-Isla T, Moss M, et al. Use of structural magnetic resonance imaging to predict who will get Alzheimer's disease.[see comment]. Annals of Neurology. 2000;47(4):430-439. [pmid: 10762153].
Maunoury C, Michot JL, Caillet H, et al. Specificity of temporal amygdala atrophy in Alzheimer's disease: quantitative assessment with magnetic resonance imaging. Dementia. 1996;7(1):10-14. [pmid: 8788076].
Miller BL, Ikonte C, Ponton M, et al. A study of the Lund-Manchester research criteria for frontotemporal dementia: clinical and single-photon emission CT correlations. Neurology. 1997;48(4):937-942. [pmid: 9109881].
Nobili F, Koulibaly M, Vitali P, et al. Brain perfusion follow-up in Alzheimer's patients during treatment with acetylcholinesterase inhibitors. Journal of Nuclear Medicine. 2002;43(8):983-990. [pmid: 12163621].
Pavics L, Grunwald F, Reichmann K, et al. Regional cerebral blood flow single-photon emission tomography with 99mTc-HMPAO and the acetazolamide test in the evaluation of vascular and Alzheimer's dementia. European Journal of Nuclear Medicine. 1999;26(3):239-245. [pmid: 10079314].
Silverman DH, Truong CT, Kim SK, et al. Prognostic value of regional cerebral metabolism in patients undergoing dementia evaluation: comparison to a quantifying parameter of subsequent cognitive performance and to prognostic assessment without PET. Molecular Genetics and Metabolism. 2003;80:350-355. [pmid: 14680983].
Smith CD, Andersen AH, Kryscio RJ, et al. Altered brain activation in cognitively intact individuals at high risk for Alzheimer's disease. Neurology. 1999;53(7):1391-1396. [pmid: 10534240].
Starkstein SE, Sabe L, Vazquez S, et al. Neuropsychological, psychiatric, and cerebral blood flow findings in vascular dementia and Alzheimer's disease. Stroke. 1996;27(3):408-414. [pmid: 8610304].
Steinling M, Defebvre L, Duhamel A, et al. Is there a typical pattern of brain SPECT imaging in Alzheimer's disease?. Dementia & Geriatric Cognitive Disorders. 2001;12(6):371-378. [pmid: 11598308].
Talbot PR, Snowden JS, Lloyd JJ, et al. The contribution of single photon emission tomography to the clinical differentiation of degenerative cortical brain disorders. Journal of Neurology. 1995;242(9):579-586. [pmid: 8551319].
Varma AR, Talbot PR, Snowden JS, et al. A 99mTc-HMPAO single-photon emission computed tomography study of Lewy body disease. Journal of Neurology. 1997;244(6):349-359. [pmid: 9249619].
Walker Z, Costa DC, Janssen AG, et al. Dementia with lewy bodies: a study of post-synaptic dopaminergic receptors with iodine-123 iodobenzamide single-photon emission tomography. European Journal of Nuclear Medicine. 1997;24(6):609-614. [pmid: 9169566].
Weiss U, Bacher R, Vonbank H, et al. Cognitive impairment: assessment with brain magnetic resonance imaging and proton magnetic resonance spectroscopy. Journal of Clinical Psychiatry. 2003;64(3):235-242. [pmid: 12716263].
Yamaguchi S, Nakagawa T, Arai H, et al. Temporal progression of hippocampal atrophy and apolipoprotein E gene in Alzheimer's disease. Journal of the American Geriatrics Society. 1996;44(2):216-217. [pmid: 8576522].

## Excluded Studies – less than 12 patients per study group

Catani M, Piccirilli M, Cherubini A, et al. Axonal injury within language network in primary progressive aphasia. Annals of Neurology. 2003;53(2):242-247. [pmid: 12557292].
Constans JM, Meyerhoff DJ, Gerson J, et al. H-1 MR spectroscopic imaging of white matter signal hyperintensities: Alzheimer disease and ischemic vascular dementia. Radiology. 1995;197(2):517-523. [pmid: 7480705].
Donnemiller E, Heilmann J, Wenning GK, et al. Brain perfusion scintigraphy with 99mTc-HMPAO or 99mTc-ECD and 123I-beta-CIT single-photon emission tomography in dementia of the Alzheimer-type and diffuse Lewy body disease. European Journal of Nuclear Medicine. 1997;24(3):320-325. [pmid: 9143472].
Fox NC, Freeborough PA, Rossor MN. Visualisation and quantification of rates of atrophy in Alzheimer's disease.[see comment]. Lancet. 1996;348(9020):94-97. [pmid: 8676724].
Fox NC, Warrington EK, Stevens JM, et al. Atrophy of the hippocampal formation in early familial Alzheimer's disease. A longitudinal MRI study of at-risk members of a family with an amyloid precursor protein 717Val-Gly mutation. Annals of the New York Academy of Sciences. Jan. 17. 1996;777:226-232. 1996. [pmid: 8624089].
Frisoni GB, Bianchetti A, Trabucchi M, et al. The added value of neuroimaging for diagnosing dementia. Ajnr: American Journal of Neuroradiology. 1999;20(5):947-949. [pmid: 10369375].
Hanyu H, Sakurai H, Iwamoto T, et al. Diffusion-weighted MR imaging of the hippocampus and temporal white matter in Alzheimer's disease. Journal of the Neurological Sciences. 1998;156(2):195-200. [pmid: 9588857].
Julin P, Lindqvist J, Svensson L, et al. MRI-guided SPECT measurements of medial temporal lobe blood flow in Alzheimer's disease. Journal of Nuclear Medicine. 1997;38(6):914-919. [pmid: 9189141].
Petrella JR, Lustig C, Bucher LA, et al. Prefrontal activation patterns in subjects at risk for Alzheimer disease. American Journal of Geriatric Psychiatry. 2002;10(1):112-113. [pmid: 11790642].
Rose SE, Chen F, Chalk JB, et al. Loss of connectivity in Alzheimer's disease: an evaluation of white matter tract integrity with colour coded MR diffusion tensor imaging. Journal of Neurology, Neurosurgery & Psychiatry. 2000;69(4):528-530.

## Excluded Studies – AD patients only

Antuono PG, Jones JL, Wang Y, et al. Decreased glutamate + glutamine in Alzheimer's disease detected in vivo with (1)H-MRS at 0.5 T. Neurology. 2001;56(6):737-742. [pmid: 11274307].
Bozzali M, Franceschi M, Falini A, et al. Quantification of tissue damage in AD using diffusion tensor and magnetization transfer MRI. Neurology. 2001;57(6):1135-1137. [pmid: 11571355].
Bozzao A, Floris R, Baviera ME, et al. Diffusion and perfusion MR imaging in cases of Alzheimer's disease: correlations with cortical atrophy and lesion load.[see comment]. Ajnr: American Journal of Neuroradiology. 2001;22(6):1030-1036. [pmid: 11415893].
Catani M, Cherubini A, Howard R, et al. (1)H-MR spectroscopy differentiates mild cognitive impairment from normal brain aging. Neuroreport. 2001;12(11):2315-2317. [pmid: 11496102].
Chantal S, Labelle M, Bouchard RW, et al. Correlation of regional proton magnetic resonance spectroscopic metabolic changes with cognitive deficits in mild Alzheimer disease. Archives of Neurology. 2002;59(6):955-962. [pmid: 12056931].
De Santi S, de Leon MJ, Rusinek H, et al. Hippocampal formation glucose metabolism and volume losses in MCI and AD. Neurobiology of Aging. 2001;22(4):529-539. [pmid: 11445252].
Ebmeier KP, Glabus MF, Prentice N, et al. A voxel-based analysis of cerebral perfusion in dementia and depression of old age. Neuroimage. 1998;7(3):199-208. [pmid: 9597661].
Forstl H, Zerfass R, Geiger-Kabisch C, et al. Brain atrophy in normal ageing and Alzheimer's disease. Volumetric discrimination and clinical correlations. British Journal of Psychiatry. 1995;167(6):739-746. [pmid: 8829740].
Hanyu H, Asano T, Sakurai H, et al. Diffusion-weighted and magnetization transfer imaging of the corpus callosum in Alzheimer's disease. Journal of the Neurological Sciences. 1999;167(1):37-44. [pmid: 10500260].
Herholz K, Schopphoff H, Schmidt M, et al. Direct comparison of spatially normalized PET and SPECT scans in Alzheimer's disease. Journal of Nuclear Medicine. 2002;43(1):21-26. [pmid: 11801698].
Huang W, Alexander GE, Chang L, et al. Brain metabolite concentration and dementia severity in Alzheimer's disease: a (1)H MRS study. Neurology. 2001;57(4):626-632. [pmid: 11524470].
Kantarci K, Jack CR Jr, Xu YC, et al. Regional metabolic patterns in mild cognitive impairment and Alzheimer's disease: A 1H MRS study. Neurology. 2000;55(2):210-217. [pmid: 10908893].
Kantarci K, Xu Y, Shiung MM, et al. Comparative diagnostic utility of different MR modalities in mild cognitive impairment and Alzheimer's disease. Dementia & Geriatric Cognitive Disorders. 2002;14(4):198-207. [pmid: 12411762].
Pantel J, Schroder J, Schad LR, et al. Quantitative magnetic resonance imaging and neuropsychological functions in dementia of the Alzheimer type. Psychological Medicine. 1997;27(1):221-229. [pmid: 9122303].
Rombouts SA, Barkhof F, Veltman DJ, et al. Functional MR imaging in Alzheimer's disease during memory encoding. Ajnr: American Journal of Neuroradiology. 2000;21(10):1869-1875. [pmid: 11110539].

## Excluded Studies – Not Relevant

Lindau M, Almkvist O, Kushi J, et al. First symptoms--frontotemporal dementia versus Alzheimer's disease. Dementia & Geriatric Cognitive Disorders. 2000;11(5):286-293. [pmid: 10940680].
Mendez MF, Perryman KM, Miller BL, et al. Compulsive behaviors as presenting symptoms of frontotemporal dementia. Journal of Geriatric Psychiatry & Neurology. 1997;10(4):154-157. [pmid: 9453681].
Pohjasvaara T, Erkinjuntti T, Ylikoski R, et al. Clinical determinants of poststroke dementia. Stroke. 1998;29(1):75-81. [pmid: 9445332].
Pohjasvaara T, Mantyla R, Aronen HJ, et al. Clinical and radiological determinants of prestroke cognitive decline in a stroke cohort. Journal of Neurology, Neurosurgery & Psychiatry. 1999;67(6):742-748.
Steffens DC, Payne ME, Greenberg DL, et al. Hippocampal volume and incident dementia in geriatric depression. American Journal of Geriatric Psychiatry. 2002;10(1):62-71. [pmid: 11790636].
Zhu XP, Du AT, Jahng GH, et al. Magnetic resonance spectroscopic imaging reconstruction with deformable shape-intensity models. Magnetic Resonance in Medicine. 2003;50(3):474-482. [pmid: 12939754].