# BIBLIOGRAPHY

Antuono PG, Jones JL, Wang Y, et al. Decreased glutamate + glutamine in Alzheimer's disease detected in vivo with (1)H-MRS at 0.5 T. Neurology. 2001;56(6):737-742. [pmid: 11274307].
Arnaiz E, Jelic V, Almkvist O, et al. Impaired cerebral glucose metabolism and cognitive functioning predict deterioration in mild cognitive impairment. Neuroreport. 2001;12(4):851-855. [pmid: 11277595].
Block W, Traber F, Flacke S, et al. In-vivo proton MR-spectroscopy of the human brain: assessment of N-acetylaspartate (NAA) reduction as a marker for neurodegeneration. Amino Acids. 2002;23(1–3):317-323. [pmid: 12373553].
Bohnen NI, Kaufer DI, Ivanco LS, et al. Cortical cholinergic function is more severely affected in parkinsonian dementia than in Alzheimer disease: an in vivo positron emission tomographic study. Archives of Neurology. 2003;60(12):1745-1748. [pmid: 14676050].
Bookheimer SY, Strojwas MH, Cohen MS, et al. Patterns of brain activation in people at risk for Alzheimer's disease.[see comment]. New England Journal of Medicine. 2000;343(7):450-456. [pmid: 10944562].
Bozzali M, Franceschi M, Falini A, et al. Quantification of tissue damage in AD using diffusion tensor and magnetization transfer MRI. Neurology. 2001;57(6):1135-1137. [pmid: 11571355].
Bozzao A, Floris R, Baviera ME, et al. Diffusion and perfusion MR imaging in cases of Alzheimer's disease: correlations with cortical atrophy and lesion load.[see comment]. Ajnr: American Journal of Neuroradiology. 2001;22(6):1030-1036. [pmid: 11415893].
Burn DJ, O'Brien JT. Use of functional imaging in Parkinsonism and dementia. Movement Disorders. Suppl 6. 2003;18:S88-S95. [pmid: 14502661].
Catani M, Cherubini A, Howard R, et al. (1)H-MR spectroscopy differentiates mild cognitive impairment from normal brain aging. Neuroreport. 2001;12(11):2315-2317. [pmid: 11496102].
Catani M, Piccirilli M, Cherubini A, et al. Axonal injury within language network in primary progressive aphasia. Annals of Neurology. 2003;53(2):242-247. [pmid: 12557292].
Chantal S, Labelle M, Bouchard RW, et al. Correlation of regional proton magnetic resonance spectroscopic metabolic changes with cognitive deficits in mild Alzheimer disease. Archives of Neurology. 2002;59(6):955-962. [pmid: 12056931].
Charpentier P, Lavenu I, Defebvre L, et al. Alzheimer's disease and frontotemporal dementia are differentiated by discriminant analysis applied to (99m)Tc HmPAO SPECT data. Journal of Neurology, Neurosurgery & Psychiatry. 2000;69(5):661-663.
Chetelat G, Desgranges B, de la Sayette V, et al. Mild cognitive impairment: Can FDG-PET predict who is to rapidly convert to Alzheimer's disease?. Neurology. 2003;60(8):1374-1377. [pmid: 12707450].
Constans JM, Meyerhoff DJ, Gerson J, et al. H-1 MR spectroscopic imaging of white matter signal hyperintensities: Alzheimer disease and ischemic vascular dementia. Radiology. 1995;197(2):517-523. [pmid: 7480705].
Corkin S. Functional MRI for studying episodic memory in aging and Alzheimer's disease. [Review] [10 refs]. 1998.
de Leon MJ, Convit A, Wolf OT, et al. Prediction of cognitive decline in normal elderly subjects with 2-[(18)F]fluoro-2-deoxy-D-glucose/poitron-emission tomography (FDG/PET). Proceedings of the National Academy of Sciences of the United States of America. 2001;98(19):10966-10971. [pmid: 11526211].
De Santi S, de Leon MJ, Rusinek H, et al. Hippocampal formation glucose metabolism and volume losses in MCI and AD. Neurobiology of Aging. 2001;22(4):529-539. [pmid: 11445252].
Defebvre LJ, Leduc V, Duhamel A, et al. Technetium HMPAO SPECT study in dementia with Lewy bodies, Alzheimer's disease and idiopathic Parkinson's disease. Journal of Nuclear Medicine. 1999;40(6):956-962. [pmid: 10452310].
Dickerson BC, Goncharova I, Sullivan MP, et al. MRI-derived entorhinal and hippocampal atrophy in incipient and very mild Alzheimer's disease. Neurobiology of Aging. 2001;22(5):747-754. [pmid: 11705634].
Dijkhuizen RM, Nicolay K. Magnetic resonance imaging in experimental models of brain disorders. Journal of Cerebral Blood Flow & Metabolism. 2003;23(12):1383-1402. [pmid: 14663334].
Donnemiller E, Heilmann J, Wenning GK, et al. Brain perfusion scintigraphy with 99mTc-HMPAO or 99mTc-ECD and 123I-beta-CIT single-photon emission tomography in dementia of the Alzheimer-type and diffuse Lewy body disease. European Journal of Nuclear Medicine. 1997;24(3):320-325. [pmid: 9143472].
Doraiswamy PM, Charles HC, Krishnan KR. Prediction of cognitive decline in early Alzheimer's disease. Lancet. 1998;352(9141):1678. [pmid: 9853445].
Ebmeier KP, Glabus MF, Prentice N, et al. A voxel-based analysis of cerebral perfusion in dementia and depression of old age. Neuroimage. 1998;7(3):199-208. [pmid: 9597661].
Executive Committee Working Group. Recommendations for Evaluating Effectiveness; Executive Committee Working Group Medicare Coverage Policy [On-line]. Baltimore, MD. Medicare Coverage Advisory Committee. 2001. Available at http://www.cms.hhs.gov/mcac/8b1-i9.asp. Accessed March 8, 2004.
Felber SR. Magnetic resonance in the differential diagnosis of dementia. Journal of Neural Transmission. 2002;109(7–8):1045-1051. [pmid: 12111442].
Forstl H, Zerfass R, Geiger-Kabisch C, et al. Brain atrophy in normal ageing and Alzheimer's disease. Volumetric discrimination and clinical correlations. British Journal of Psychiatry. 1995;167(6):739-746. [pmid: 8829740].
Fox NC, Crum WR, Scahill RI, et al. Imaging of onset and progression of Alzheimer's disease with voxel-compression mapping of serial magnetic resonance images. Lancet. 2001;358(9277):201-205. [pmid: 11476837].
Fox NC, Freeborough PA, Rossor MN. Visualisation and quantification of rates of atrophy in Alzheimer's disease.[see comment]. Lancet. 1996;348(9020):94-97. [pmid: 8676724].
Fox NC, Warrington EK, Stevens JM, et al. Atrophy of the hippocampal formation in early familial Alzheimer's disease. A longitudinal MRI study of at-risk members of a family with an amyloid precursor protein 717Val-Gly mutation. Annals of the New York Academy of Sciences. Jan. 17. 1996;777:226-232. 1996. [pmid: 8624089].
Frisoni GB, Bianchetti A, Trabucchi M, et al. The added value of neuroimaging for diagnosing dementia. Ajnr: American Journal of Neuroradiology. 1999;20(5):947-949. [pmid: 10369375].
Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Medical Decision Making. 1991;11(2):88-94. [pmid: 1907710].
Gill SS, Rochon PA, Guttman M, et al. The value of positron emission tomography in the clinical evaluation of dementia. Journal of the American Geriatrics Society. 2003;51(2):258-264. [pmid: 12558725].
Grundman M, Sencakova D, Jack CR Jr, et al. Brain MRI hippocampal volume and prediction of clinical status in a mild cognitive impairment trial. Journal of Molecular Neuroscience. 2002;19(1–2):23-27. [pmid: 12212787].
Hanyu H, Asano T, Sakurai H, et al. Diffusion-weighted and magnetization transfer imaging of the corpus callosum in Alzheimer's disease. Journal of the Neurological Sciences. 1999;167(1):37-44. [pmid: 10500260].
Hanyu H, Sakurai H, Iwamoto T, et al. Diffusion-weighted MR imaging of the hippocampus and temporal white matter in Alzheimer's disease. Journal of the Neurological Sciences. 1998;156(2):195-200. [pmid: 9588857].
Herholz K, Schopphoff H, Schmidt M, et al. Direct comparison of spatially normalized PET and SPECT scans in Alzheimer's disease. Journal of Nuclear Medicine. 2002;43(1):21-26. [pmid: 11801698].
Huang W, Alexander GE, Chang L, et al. Brain metabolite concentration and dementia severity in Alzheimer's disease: a (1)H MRS study. Neurology. 2001;57(4):626-632. [pmid: 11524470].
Institute for Clinical Evaluative Sciences. Health Technology Assessment of Positron Emission Tomography [Online]. Toronto, Ontario. Institute of Clinical Evaluative Sciences. 2001. Available at http://www.ices.on.ca. Accessed on March 22, 2004.
Jack CR Jr, Petersen RC, Xu Y, et al. Rates of hippocampal atrophy correlate with change in clinical status in aging and AD. Neurology. 2000;55(4):484-489. [pmid: 10953178].
Jack CR Jr, Petersen RC, Xu YC, et al. Prediction of AD with MRI-based hippocampal volume in mild cognitive impairment. Neurology. 1999;52(7):1397-1403. [pmid: 10227624].
Jack CR Jr, Petersen RC, Xu YC, et al. Rate of medial temporal lobe atrophy in typical aging and Alzheimer’s disease. Neurology. 1998;51:993-999. [pmid: 9781519].
Jack CR Jr, Shiung MM, Gunter BL, et al. Comparison of different MRI brain atrophy rate measures with clinical disease progression in AD. Neurology. 2004;62:591-600. [pmid: 14981176].
Jessen F, Block W, Traber F, et al. Decrease of N-acetylaspartate in the MTL correlates with cognitive decline of AD patients. Neurology. 2001;57(5):930-932. [pmid: 11552037].
Jobst KA, Barnetson LP, Shepstone BJ. Accurate prediction of histologically confirmed Alzheimer's disease and the differential diagnosis of dementia: the use of NINCDS-ADRDA and DSM-III-R criteria, SPECT, X-ray CT, and Apo E4 in medial temporal lobe dementias. Oxford Project to Investigate Memory and Aging.[republished from Int Psychogeriatr. 1997;9 Suppl 1:191–222; discussion 247–52; PMID: 9447442]. International Psychogeriatrics. 1998;10(3):271-302. [pmid: 9785148].
Johnson KA, Lopera F, Jones K, et al. Presenilin-1-associated abnormalities in regional cerebral perfusion. Neurology. 2001;56(11):1545-1551. [pmid: 11402113].
Julin P, Lindqvist J, Svensson L, et al. MRI-guided SPECT measurements of medial temporal lobe blood flow in Alzheimer's disease. Journal of Nuclear Medicine. 1997;38(6):914-919. [pmid: 9189141].
Kantarci K, Jack CR Jr, Xu YC, et al. Regional metabolic patterns in mild cognitive impairment and Alzheimer's disease: A 1H MRS study. Neurology. 2000;55(2):210-217. [pmid: 10908893].
Kantarci K, Jack CR Jr, Xu YC, et al. Mild cognitive impairment and Alzheimer disease: regional diffusivity of water. Radiology. 2001;219(1):101-107. [pmid: 11274543].
Kantarci K, Xu Y, Shiung MM, et al. Comparative diagnostic utility of different MR modalities in mild cognitive impairment and Alzheimer's disease. Dementia & Geriatric Cognitive Disorders. 2002;14(4):198-207. [pmid: 12411762].
Killiany RJ, Gomez-Isla T, Moss M, et al. Use of structural magnetic resonance imaging to predict who will get Alzheimer's disease.[see comment]. Annals of Neurology. 2000;47(4):430-439. [pmid: 10762153].
Matchar DB, Kulasingam SL, McCrory DC, et al. Use of Positron Emission Tomography and other neuroimaging techniques in the diagnosis and management of Alzheimer’s disease and dementia. Prepared for the Agency for Healthcare Research and Quality.Contract No. 290-97-0014, Task Order 7. 2001. Dec. 14.
Maunoury C, Michot JL, Caillet H, et al. Specificity of temporal amygdala atrophy in Alzheimer's disease: quantitative assessment with magnetic resonance imaging. Dementia. 1996;7(1):10-14. [pmid: 8788076].
McMahon PM, Araki SS, Sandberg EA, Neumann PJ, Gazelle GS. Cost-effectiveness of PET in the diagnosis of Alzheimer disease. Radiology. 2003;228(2):515-522. [pmid: 12802006].
Miller BL, Ikonte C, Ponton M, et al. A study of the Lund-Manchester research criteria for frontotemporal dementia: clinical and single-photon emission CT correlations. Neurology. 1997;48(4):937-942. [pmid: 9109881].
Neirinckx RD, Canning LR, Piper IM, et al. Technetium 99m d,l-HMPAO: a new radiopharmaceutical for SPECT imaging of regional cerebral blood perfusion. Journal of Nuclear Medicine. 1987;28:191-202. [pmid: 3492596].
Nobili F, Koulibaly M, Vitali P, et al. Brain perfusion follow-up in Alzheimer's patients during treatment with acetylcholinesterase inhibitors. Journal of Nuclear Medicine. 2002;43(8):983-990. [pmid: 12163621].
Pantel J, Schroder J, Schad LR, et al. Quantitative magnetic resonance imaging and neuropsychological functions in dementia of the Alzheimer type. Psychological Medicine. 1997;27(1):221-229. [pmid: 9122303].
Pavics L, Grunwald F, Reichmann K, et al. Regional cerebral blood flow single-photon emission tomography with 99mTc-HMPAO and the acetazolamide test in the evaluation of vascular and Alzheimer's dementia. European Journal of Nuclear Medicine. 1999;26(3):239-245. [pmid: 10079314].
Petrella JR, Colemen RE, Doraiswamy PM. Neuroimaging and early diagnosis of Alzheimer disease: A look into the future. Radiology. 2003;226:315-336. [pmid: 12563122].
Petrella JR, Lustig C, Bucher LA, et al. Prefrontal activation patterns in subjects at risk for Alzheimer disease. American Journal of Geriatric Psychiatry. 2002;10(1):112-113. [pmid: 11790642].
Pickut BA, Dierckx RA, Dobbeleir A, et al. Validation of the cerebellum as a reference region for SPECT quantification in patients suffering from dementia of the Alzheimer type. Psychiatry Res. 1999;90:103-112. [pmid: 10482382].
Ricci PE Jr. Proton MR spectroscopy in ischemic stroke and other vascular disorders. Neuroimaging Clinics of North America. 1998;8(4):881-900. [pmid: 9769348].
Rombouts SA, Barkhof F, Veltman DJ, et al. Functional MR imaging in Alzheimer's disease during memory encoding. Ajnr: American Journal of Neuroradiology. 2000;21(10):1869-1875. [pmid: 11110539].
Rose SE, Chen F, Chalk JB, et al. Loss of connectivity in Alzheimer's disease: an evaluation of white matter tract integrity with colour coded MR diffusion tensor imaging. Journal of Neurology, Neurosurgery & Psychiatry. 2000;69(4):528-530.
Rosen AC, Bokde AL, Pearl A, Yesavage JA. Ethical, and practical issues in applying functional imaging to the clinical management of Alzheimer's disease. Brain & Cognition. 2002;50(3):498-519. [pmid: 12480493].
Rothman KJ, Greenland S. Modern Epidemiology. 1998. Jan. 15.
Silverman DH, Gambhir SS, Huang HW, et al. Evaluating early dementia with and without assessment of regional cerebral metabolism by PET: a comparison of predicted costs and benefits. Journal of Nuclear Medicine. 2002;43:253-266. [pmid: 11850493].
Silverman DH, Truong CT, Kim SK, et al. Prognostic value of regional cerebral metabolism in patients undergoing dementia evaluation: comparison to a quantifying parameter of subsequent cognitive performance and to prognostic assessment without PET. Molecular Genetics and Metabolism. 2003;80:350-355. [pmid: 14680983].
Smith CD, Andersen AH, Kryscio RJ, et al. Altered brain activation in cognitively intact individuals at high risk for Alzheimer's disease. Neurology. 1999;53(7):1391-1396. [pmid: 10534240].
Starkstein SE, Sabe L, Vazquez S, et al. Neuropsychological, psychiatric, and cerebral blood flow findings in vascular dementia and Alzheimer's disease. Stroke. 1996;27(3):408-414. [pmid: 8610304].
Steinling M, Defebvre L, Duhamel A, et al. Is there a typical pattern of brain SPECT imaging in Alzheimer's disease?. Dementia & Geriatric Cognitive Disorders. 2001;12(6):371-378. [pmid: 11598308].
Talbot PR, Snowden JS, Lloyd JJ, et al. The contribution of single photon emission tomography to the clinical differentiation of degenerative cortical brain disorders. Journal of Neurology. 1995;242(9):579-586. [pmid: 8551319].
Varma AR, Talbot PR, Snowden JS, et al. A 99mTc-HMPAO single-photon emission computed tomography study of Lewy body disease. Journal of Neurology. 1997;244(6):349-359. [pmid: 9249619].
Veterans Health Administration. Technology assessment report. Descriptive analysis of experience with PET in VA. A systematic review update of FDG-PET as a diagnostic test in cancer and Alzheimer’s disease [On-line]. Washington, DC. Department of Veterans’ Affairs. 2001. Available at http://www.va.gov/resdev/prt/petreport.htm. Accessed March 22, 2004.
Wagner AD. Early Detection of Alzheimer's disease: An fMRI marker for people at risk?. Nature Neuroscience. 2000;3(10):973-974.
Walker Z, Costa DC, Janssen AG, et al. Dementia with lewy bodies: a study of post-synaptic dopaminergic receptors with iodine-123 iodobenzamide single-photon emission tomography. European Journal of Nuclear Medicine. 1997;24(6):609-614. [pmid: 9169566].
Weiss U, Bacher R, Vonbank H, et al. Cognitive impairment: assessment with brain magnetic resonance imaging and proton magnetic resonance spectroscopy. Journal of Clinical Psychiatry. 2003;64(3):235-242. [pmid: 12716263].
Yamaguchi S, Nakagawa T, Arai H, et al. Temporal progression of hippocampal atrophy and apolipoprotein E gene in Alzheimer's disease. Journal of the American Geriatrics Society. 1996;44(2):216-217. [pmid: 8576522].