# UPDATED REVIEW OF THE LITERATURE REGARDING FDG-PET IN DIAGNOSING DEMENTIA

## 2.1 Original Technology Assessment

The goal of the original TA was to assess the benefits of FDG-PET scanning in patients with dementia, with mild cognitive impairment (MCI) and in asymptomatic patients with a family history of AD, subsequent to the standard evaluation as described in the American Academy of Neurology (AAN) guidelines. The assessment was accomplished by reviewing the scientific evidence regarding the performance of PET, natural history of AD, treatment efficacy and adverse effects, and creating a decision model linking testing with treatment and outcomes. The methods and results are described in detail in an evidence report (Matchar, 2002) that is available online from: http://cms.hhs.gov/coverage/download/8b3-ww3.pdf).

The findings of the original TA are consistent with previously published evidence reviews tied to models (Silverman,2001; MacMahon, 2003); namely that PET improves the overall accuracy of diagnosis compared to accuracy of an examination based on AAN guidelines. Also consistent with MacMahon et al. (2003), but in contrast to Silverman et al. (2001), the original TA concluded that treatment based on a standard AAN-recommended examination leads to better health outcomes than treatment based on PET results, and that this result is robust to a broad range of assumptions. The apparent discordance between overall accuracy and clinical benefit relates to two points recognized in both the original TA and in the MacMahon, et al analysis. First, the efficacy of currently available treatments, such as anticholinesterase inhibitors (AChEIs), has been established from trials using an examination based on AAN guidelines as the reference standard. Thus, treatment restricted to patients with a diagnostic PET result will necessarily decrease the number of patients with AD who are treated (i.e., PET results in more false negatives than an examination based on AAN guidelines); these patients will not benefit from delayed AD progression due to treatment. Second, while PET use will decrease the number of patients incorrectly labeled as having AD (and will decrease the number of these false positives more than it will increase the number of false negatives), this benefit of fewer false positives is relatively less important since AD treatments are generally benign. It is important to note that these points remain relevant for evaluation of patients who have not yet developed frank AD (since presumptive treatment may provide an even greater net benefit if it delays the onset of even mildly disabling symptoms), and for patients who are evaluated by clinicians less skilled in diagnosis of cognitive symptoms.

Three additional insights emerged from the original TA regarding when testing would be expected to improve clinical outcomes.

First, testing would be an attractive option if a new treatment becomes available that is not only more effective than AChEIs but is also associated with a risk of severe adverse effects. However, to our knowledge, no such treatment is currently available.

Second, testing would be useful if it could be demonstrated to be a better reference standard than an examination based on AAN guidelines. To the point, testing would need to better distinguish patients who respond to therapy than is possible with a standard examination. No evidence was uncovered in the original TA to indicate this was the case.

Third, testing could be useful if the results could be shown to have benefits beyond informing AchEI use. This “value of knowing” could have both positive and negative components. In any case, no PET research was identified that examines this issue empirically.

Based on these insights, we conclude that, in addition to estimating the operating characteristics of tests for the diagnosis of AD, it is crucial to understand the value of testing for estimating disease prognosis, and for predicting response to treatment (in terms of both positive and adverse effects). Here, value could include the value of knowing health status, exclusive of the utility of this information in choosing therapy.

## 2.2 Methods

### 2.2.1 Overview of the literature search

The original literature search, conducted using MEDLINE was updated to include articles that were published during and after 2001. In addition, we searched the International Network of Agencies for Health Technology Assessment (www.inahta.org) database, the National Institute for Clinical Excellence database (www.nice.org.uk), the Health Technology Assessment database (www.hta.nhsweb.nhs.uk), and the Guidelines International Net database (www.g-i-n.net) to identify pertinent evidence reports or technology assessments that may have been published in the last 3 years. References from recently published literature reviews were also searched to identify any additional technology assessments or evidence reports. The results of these searches are documented below.

### 2.2.2 Search strategy

The following is the search strategy using Ovid MEDLINE

1 | exp *alzheimer disease/di, ra (2622)
2 | exp tomography, emission-computed/ (32749)
3 | and/1–2 (190)
4 | fdg-pet.mp. (2163)
5 | 1and 4.mp. [mp=title, abstract, name of substance, mesh subject heading] (0)
6 | or/3,5 (190)
7 | limit 6 to yr=2001–2004 (57)
8 | 6 not 7 (133)
9 | pet.tw. (16087)
10 | fdg-pet.tw. (2163)
11 | exp alzheimer disease/ (31076)
12 | exp "sensitivity and specificity"/ (149939)
13 | or/2,4,9–10 (38029)
14 | or/1,11 (31076)
15 | and/13–14 (1195)
16 | 12 and 15 (110)
17 | 6 or 16 (273)
18 | limit 17 to human (269)
19 | limit 18 to english language (228)
20 | discriminant analysis/ (3400)
21 | 20 and 15 (13)
22 | risk factors/ (227494)
23 | 22 and 15 (33)
24 | case control studies/ (52837)
25 | 24 and 15 (61)
26 | Diagnosis, differential/ (239645)
27 | 26 and 15 (146)
28 | or/21,23,25,27 (235)
29 | 28 not 17 (149)
30 | limit 29 to human (149)
31 | limit 30 to english language (129)
32 | limit 31 to yr=2001–2004 (22)
33 | from 32 keep 1–22 (22)

### 2.2.3 Results of the literature review and inclusion criteria for full text article identification

No recently published TAs were listed in any of the four websites. However, two TAs were identified based on a recent review of the literature by Gill et al. (2003) (Veteran’s Health Administration, 2001; Institute for Clinical Evaluative Sciences, 2001). A review of the publications included in these technology reports did not yield new studies for inclusion, beyond those provided in our prior evidence report (Matchar, 2001)

The MEDLINE search resulted in 22 potential articles for review. Consistent with the inclusion criteria used in the original TA (Matchar, 2001) only articles that were considered Category 2 or higher using the classification scheme developed by Fryback and Thornbury (Fryback, 1991) were included for full text review. Table 1 summarizes these categories. An exception was made in the original report for Level 1 articles that examined the use of FDG-PET in AD patients and controls; these articles were included to determine the test characteristics of FDG-PET. However, for this TA, we excluded articles describing the performance of PET in patients with AD compared to normal controls. We did this for two reasons. First, such studies do not directly address the relevant clinical issue – discriminating between etiologies of cognitive symptoms – since by design the imaging study could not provide diagnostic or prognostic information beyond that available from clinical evaluation. Second, evidence from our previous review indicates that comparisons of AD and clinically normal patients leads to biased estimates of sensitivity and specificity for discriminating between AD and other etiologies of cognitive impairment. On this basis, 4 articles were identified for full text review and are described in detail in the next section.

Table 1 Fryback et al. Classification Categories (1991)

CLINICAL QUESTION | CATEGORIES | CATEGORY DESCRIPTION | MEASURES
Does the test have good technical characteristics that make it appropriate for use in a clinical setting? | 1 | Technical feasibility and optimization | Ability to produce consistent spectra
Does the test have good operating characteristics that make it useful for; 1) determining the presence of disease?; 1) determining the severity of disease?; 2) improving the yield of specimens for diagnosing disease? | 2 | Diagnostic accuracy | Sensitivity and specificity % yield of abnormal diagnoses
Does the test influence the clinicians’ subjective assessment of disease status? | 3 | Diagnostic thinking impact | Difference in clinician’s subjectively estimated diagnosis probabilities pre and post-test
Does the test influence the therapy given to a patient? | 4 | Therapeutic choice impact | % of times therapy planned prior to PET changed after PET
Does the test result in an improvement in life expectancy from the patient viewpoint? | 5 | Patient outcome impact | % of patients who improved with PET compared to % without PET Cost per QALY saved with image information
Does the test result in an improvement in life expectancy at a reasonable cost from the viewpoint of society? | 6 | Societal impact | Cost-benefit or cost-effectiveness analysis conducted from a societal viewpoint

## 2.3 Results

Of the four studies identified for full text review, one examined the use of PET in distinguishing Parkinsonian dementia from AD (Bohnen, 2003). The three other studies described the ability of FDG-PET to predict progression to AD in patients with mild cognitive impairment (Chetelat, 2003; Arnaiz 2001; Silverman 2003).

Bohnen et al (2003) used PET to examine cortical cholinergic function in patients with Parkinsonian Dementia (PDem) (n=14), AD (n=12), Parkinson’s disease without dementia (PD) and normal controls (n=10), based on earlier pathologic findings that suggested that patients with PDem have cholinergic forebrain neuronal losses that may be equivalent or greater than losses seen in patients with AD. [11C] PMP radioligand was used in conjunction with PET to determine AChE activity in the four groups. PET was conducted using an ECAT HR+ (CTI PET Systems, Knoxville, TN). Regions of interest were determined using co-registration with MRI. AD patients were recruited from the Alzheimer’s Disease Research Center at the University of Pittsburgh and diagnosed using the Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Association criteria (NINCDS-ADRDA). Patients with PD or PDem were recruited from the Movement Disorders Clinic at the University of Pittsburgh and were diagnosed using the Consortium on Dementia with Lewy Bodies criteria. Compared with controls, mean cortical AChE activity was lowest in patients with PDem, followed by patients with PD without dementia. Mean cortical AChE activity was relatively preserved in patients with AD, except for the lateral temporal cortex, suggesting that reduced cortical AChE activity may be more characteristic of patients with PDem than those with AD.

Chetelat et al. (2003) examined 17 patients with MCI at 6-month intervals for 18 months to determine a metabolic profile that could be used to predict progression to AD. Patients were classified as MCI if they did not meet the criteria for probable AD using the NINCDS-ADRDA criteria and had Mini-Mental Status Examinations (MMSE) with scores of ≥24. The authors theorized that, based on prior studies, the earliest metabolically affected areas in patients with probable AD was the posterior cingulate gyrus (PCG) followed by the temporoparietal posterior association cortex and hippocampal region. For comparison, 15 healthy controls without memory impairment were included. FDG-PET scans were obtained at entry and at each followup visit (12 months and 18 months) using the ECAT HR+ device (CTI, Knoxville, TN). Statistical parametric testing was used in determining regional activity values. These values were in turn used to determine the percent of patients correctly classified as converters and non-converters. The authors examined the results using a specified a cut-off. However, they do not make it clear if the cut-point value was determined a priori or was based on multiple comparisons. Neuropsychological testing was also conducted at baseline and at follow up, using scales to assess global functioning (Mattis), attention, verbal initiation, motor initiation, visuospatial construction, conceptualization, memory, total recall (Grober and Buschke) and delayed recall (Ray’s figure), blinded to PET results. Of the original 17 patients, 7 eventually met the inclusion criteria for probable AD. These 7 patients were termed rapid converters. Compared to non-converters, these patients were shown to have significantly lower FDG uptake, at inclusion, in the temporoparietal posterior association cortex and based on the described cut-point differentiated all converters from all non-converters. The PCG appeared to provide only marginal differentiation. During the 18 months of followup, this area continued to be significantly associated with rapid conversion suggesting its potential usefulness in distinguishing MCI rapid converters from non-converters.

Arniaz et al. (2001) followed 20 patients with MCI to determine whether reduced glucose metabolism could be used to predict progression to AD. No controls were included in this study. FDG-PET scans were obtained at entry and at approximately 3-month intervals using two scanners, the GEMS 2048-15B and GEMS 4096-15WB (General Electric Medical Systems, Milwaukee, Wisc). Neuropsychological testing was also conducted at baseline and at follow up, using scales to assess global functioning (MMSE), intelligence (information, digit span, similarities, block design and digit symbol from the Wechsler adult intelligence scale-revised), trail making tests, the Rey-Osterreith copy and retention test, the Rey auditory verbal learning test and the free recall and recognition of words from the Stockholm Geriatric Research Center. Of the original 20 patients, 9 eventually met the inclusion criteria for probable AD using the NINCDS-ADRDA criteria. Compared to patients who did not convert, converters had significantly lower baseline results in block design, digit symbol and trail making B time. They also had significantly lower uptake values in the left temporoparietal regions above the level of the basal ganglia. Using logistic regression, the authors explored different statistical models using imaging in combination with the various neuropsychological testing results to predict progression. Two variables that were consistently and significantly associated with progression were left temporoparietal glucose metabolism and performance on the block design test. These measures correctly classified 90% of patients as converters and non-converters, whereas use of either by itself gave 75% (glucose metabolism) and 65% (block design) correct classification, suggesting their potential combined use in determining progression in patients with MCI. No model examined the incremental contribution of PET to clinical findings.

Silverman et al. (2003) retrospectively assessed 167 patients with cognitive impairment referred to an academic nuclear medicine clinic for brain PET, to determine whether reduced glucose metabolism could be used to predict dementia progression. FDG-PET scans were obtained at baseline using two scanners, the Siemens/CTI ECAT 831 or 931 or the Siemens ECAT EXACT HR or HR+ scanner (CTI PET Systems, Knoxville, TN). Physicians who were blinded to clinical follow-up data read the scans and classified them as progressive or non-progressive based on criteria established a priori. Scans considered positive for signs of progression had focal cortical hypometabolism in parietal, temporal and frontal lobes, or diffuse cortical hypometabolism with sparing of sensorimotor ± visual cortex, with cortical deficits unaccounted for by matched findings on CT or MRI indicative of cerebrovascular disease. Negative scans had no abnormal findings or had abnormal findings other than those meeting the definition of a positive scan. Clinical data was based on chart review and a study questionnaire. Information recorded included handedness, indication for PET, originally reported PET findings, reported findings of CT or MRI, functional, behavioral and cognitive status, elapsed time between date of PET scan and patient’s most recent evaluation during which cognitive status could be assessed and any neuropathological findings. Progression was assessed using neuropsychiatric data obtained at least 2 years following the initial PET or at least 3 years later for patients taking cholinesterase inhibitors. Progression was independently confirmed by two board certified physicians blinded to PET findings. Since MMSE score was the most widely utilized measure across patients, scores were compared for progressors and non-progressors. Patients considered to be progressors using criteria for the PET scans had an average 4.1 points lower MMSE score (compared to baseline) whereas non-progressors had an average difference of 2.1 points over the same interval although these differences were not statistically significant. One hundred and twenty eight patients also had clinical data available for assessment of progression obtained at the time of PET. Of these, 58 were classified as having progressive dementia using clinical criteria, 44 were classified as having a non-progressive dementia and 26 had an indeterminable diagnosis. Of the 102 patients with a clinical diagnosis 64 patients were eventually considered to have met the criteria for progression; 38 patients were considered non-progressors. The sensitivity of clinical exam for predicting progression 77% (95%: CI 66–87%) and specificity was 76% (95%CI: 63–90%). For this same group of patients, sensitivity of PET was 95% (95%: CI 90–100%) and specificity was 79% (95% CI: 66–92%). Information on specific cause for progression was not presented.

## 2.4 Conclusions

Publications since the prior TA do not provide evidence supporting revised estimates of the operating characteristics of PET for discriminating AD from other competing diagnoses. The one included study examined a variant of PET involving a radioligand other than FDG and thus is not clearly relevant to current or near-term clinical practice. Three studies suggest FDG-PET could be valuable for distinguishing patients with MCI who rapidly convert to frank AD. Two were relatively small studies that require validation and assessment of incremental value above conventional clinical measures. A third, larger study of FDG PET for prediction of progression for patients with MCI also suggests a potential role for PET in predicting clinical course for patients with dementia. However, this study did not comment on findings for patients with AD only, and results for PET, while suggestive of higher sensitivity and specificity, did not differ in a statistically significant manner from clinical findings.