# INTRODUCTION

## 1.1 Overview

In December of 2001, the Duke Evidence Practice Center (EPC) completed a technology assessment to review the existing scientific evidence with regard to the role of 2-Fluoro 2-deoxy D-glucose Positron Emission Tomography (FDG-PET) in assisting with the diagnosis of early dementia in elderly patients for whom the differential diagnosis includes one or more kinds of neurodegenerative disease. This technology assessment informed a decision by the Centers for Medicare & Medicaid Services (CMS). CMS is now reconsidering this decision and has requested an update of the technology assessment.

In addition, CMS has requested that the Duke EPC review the existing scientific evidence with regard to the role of single-photon emission CT (SPECT), volumetric assessment by computed tomography or magnetic resonance imaging (Volumetric CT/MRI), functional magnetic resonance imaging (fMRI), and magnetic resonance spectroscopy (MRS) in the diagnosis, prognosis and estimates of responsiveness to treatment for patients with cognitive abnormalities.

## 1.2 Request by the Centers for Medicare and Medicaid Services

The Duke EPC was asked by the Agency for Health Care Research and Quality (AHRQ) to conduct an assessment to answer two questions raised by the Centers for Medicare & Medicaid Services (CMS):

1. What is the new clinical data on the use of PET in the diagnosis of early dementia in elderly patients published since 2001, the end date for the previous technology assessment (TA)? The new TA should include any articles on use of PET to distinguish patients with AD from those with other causes of symptoms confounding the diagnosis of dementia, or to assist with the diagnosis of early dementia in individuals for whom the differential diagnosis includes one or more kinds of neurodegenerative disease. The TA will include a summary of the data, a critical appraisal of the quality of the studies, and an analysis of how these new data might change the 2001 analysis.
2. What clinical data is available on the use of SPECT, Volumetric CT/MRI, fMRI and MRS in the diagnosis of early dementia in elderly patients, published after 1995? The response to this questions should be a structured, annotated review, organized by key issues for policy makers, including the following:
  a. Studies on the use of the technology to discriminate between AD and other causes of cognitive impairment
  b. Studies that predict prognosis for the natural history of disease
  c. Studies that predict response to treatment, in terms of both positive and adverse effects

In addition, we sought studies on potential harms and benefits of testing and the “value of knowing” (i.e. impact of being told test results – positive or negative – on non-medical decision making and general quality of life).

## 1.3 Structure of the Evidence Report

In order to address the questions posed by CMS and for ease in reading and comprehension, the report is separated into two sections corresponding to the two questions. The first section is an updated literature review regarding the role of FDG-PET in the diagnosis of dementia in elderly patients and is organized as follows:

A brief overview of the goals and results of the previous TA (Matchar, 2001) is followed by a discussion of methods used to identify and review new literature. This is followed by a detailed description of articles meeting all inclusion criteria. The section is concluded by a summary statement regarding the effect the update has on the original report.

The second section addresses the second question regarding clinical research studies on the use of SPECT, Volumetric CT/MRI, fMRI and MRS in the diagnosis, prognosis, and predicted treatment response of early dementia in elderly patients. After a brief overview of the issues addressed in the literature and rationale for the overall organization of articles within the report, the technologies assessed and their application in patients with cognitive impairment is described. A methods section outlines the literature search, detailed inclusion criteria and a list of characteristics reported for each evaluated article. The results section is organized by application of the technologies (i.e., diagnosis, prognosis, or predicted response to treatment). Within each application the studies are listed by Fryback and Thornbury categories (Fryback, 1991) (described in more detail below, Section 2.2.3).