# Details of relevant excluded articles

Table 7 Excluded studies – less than 12 patients per group

Author | Enrollment (consecutive or random) | RCT | Comparability (matching or adjusted) | Defined reference standard | Radiologist blinded to clinical info | A priori criteria for test +/− | If a priori criteria were available could 2×2 table be made
SPECT
Julin P, Lindqvist J, Svensson L, et al (1997) | No | No | Yes | Yes | NR | No | No
Donnemiller E, Heilmann J, Wenning GK, et al (1997) | No | No | No | Yes | Yes | No | Yes
Volumetric CT/MRI
Fox NC, Crum WR, Scahill RI, et al (2001) | No | No | No | Yes | Yes | No | No
Rose SE, Chen F, Chalk JB, et al (2000) | No | No | No | Yes | NR | No | No
Frisoni GB, Bianchetti A, Trabucchi M, et al (1999) | No | No | No | Yes | NR | No | No
Hanyu H, Sakurai H, Iwamoto T, et al (1998) | No | No | Yes | Yes | Yes | No | No
Fox NC, Freeborough PA, Rossor MN (1996) | No | No | Yes | Yes | NR | No | No
Fox NC, Warrington EK, Stevens JM, et al (1996) | No | No | No | Yes | Yes | No | No
fMRI
Petrella JR, Lustig C, Bucher LA, et al (2002) | No | No | No | Yes | Yes | No | No
MRS
Catani M, Piccirilli M, Cherubini A, et al (2003) | No | No | Yes | Yes | NR | No | Yes
Constans JM, Meyerhoff DJ, Gerson J, et al (1995) | No | No | No | Yes | Yes | No | No

Table 8 Excluded studies – Alzheimer’s disease patients only

Author | Enrollment (consecutive or random) | RCT | Comparability (matching or adjusted) | Defined reference standard | Radiologist blinded to clinical info | A priori criteria for test +/− | If a priori criteria were available could 2×2 table be made
SPECT
Herholz K, Schopphoff H, Schmidt M, et al (2002) | No | No | No | Yes | Yes | No | No
Ebmeier KP, Glabus MF, Prentice N, et al (1998) | No | No | No | Yes | NR | No | No
Volumetric CT/MRI
Bozzali M, Franceschi M, Falini A, et al (2001) | Yes | No | Yes | Yes | NR | No | No
Bozzao A, Floris R, Baviera ME, et al (2001) | Yes | No | Yes | Yes | NR | No | No
De Santi S, de Leon MJ, Rusinek H, et al (2001) | No | No | Yes | Yes | NR | No | No
Kantarci K, Jack CR Jr, Xu YC, et al (2001) | Yes | No | No | Yes | Yes | No | No
Hanyu H, Asano T, Sakurai H, et al (1999) | No | No | Yes | Yes | Yes | No | No
Pantel J, Schroder J, Schad LR, et al (1997) | No | No | Yes | Yes | Yes | No | No
Forstl H, Zerfass R, Geiger-Kabisch C, et al (1995) | No | No | Yes | Yes | NR | No | Yes
fMRI
Rombouts SA, Barkhof F, Veltman DJ, et al (2000) | Yes | No | Yes | Yes | NR | No | No
MRS
Chantal S, Labelle M, Bouchard RW, et al (2002) | No | No | Yes | Yes | NR | No | No
Kantarci K, Xu Y, Shiung MM, et al. (2002) | Yes | No | Yes | Yes | Yes | No | No
Antuono PG, Jones JL, Wang Y, et al. (2001) | No | No | Yes | Yes | Yes | No | Yes
Catani M, Cherubini A, Howard R, et al. (2001) | No | No | No | Yes | NR | No | Yes
Huang W, Alexander GE, Chang L, et al. (2001) | No | No | Yes | Yes | NR | No | No
Kantarci K, Jack CR Jr, Xu YC, et al (2000) | No | No | No | Yes | NR | No | Yes