# Literature search results for second question posed by CMS

## Literature search results for SPECT

Ovid Technologies, Inc. Email Service

------------------------------

Search for: limit 30 to english language

Citations: 1–125

Database: Ovid MEDLINE(R) <1966 to January Week 4 2004>

Search Strategy:

1 | exp *alzheimer disease/di, ra (2639)
2 | exp Tomography,Emission-computed, Single-photon/ (13638)
3 | and/1–2 (118)
4 | tomography.mp. (92925)
5 | 1 and 4 (184)
6 | or/3,5 (244)
7 | limit 6 to yr=1995–2004 (143)
8 | 6 not 7 (101)
9 | single-photon emission-computed tomography.tw. (4725)
10 | tomography.tw. (88872)
11 | exp alzheimer disease/ (31261)
12 | exp "sensitivity and specificity"/ (151518)
13 | or/2,4,9–10 (100910)
14 | or/1,11 (31261)
15 | and/13–14 (1142)
16 | 12 and 15 (106)
17 | 6 or 16 (315)
18 | limit 17 to human (312)
19 | limit 18 to english language (263)
20 | discriminant analysis/ (3416)
21 | 20 and 15 (14)
22 | risk factors/ (229013)
23 | 22 and 15 (32)
24 | case control studies/ (53391)
25 | 24 and 15 (56)
26 | Diagnosis, differential/ (240645)
27 | 26 and 15 (165)
28 | or/21,23,25,27 (247)
29 | 28 not 18 (145)
30 | limit 29 to human (145)
31 | limit 30 to english language (125)
32 | from 31 keep 1–125 (125)

## Literature search results for CT

Ovid Technologies, Inc. Email Service

------------------------------

Search for: limit 30 to english language

Citations: 1–144

Database: Ovid MEDLINE(R) <1966 to January Week 4 2004>

Search Strategy:

1 | exp *alzheimer disease/di, ra (2639)
2 | exp Tomography,Emission-computed/ (32929)
3 | and/1–2 (192)
4 | tomography.mp. (92925)
5 | 1 and 4 (184)
6 | or/3,5 (279)
7 | limit 6 to yr=1995–2004 (163)
8 | 6 not 7 (116)
9 | (computed tomography or CT scan or CAT scan).mp. [mp=title, abstract, name of substance, mesh subject heading] (69856)
10 | tomography.tw. (88872)
11 | exp alzheimer disease/ (31261)
12 | exp "sensitivity and specificity"/ (151518)
13 | or/2,4,9–10 (122995)
14 | or/1,11 (31261)
15 | and/13–14 (1416)
16 | 12 and 15 (128)
17 | 6 or 16 (368)
18 | limit 17 to human (364)
19 | limit 18 to english language (310)
20 | discriminate analysis/ (0)
21 | 20 and 15 (0)
22 | risk factors/ (229013)
23 | 22 and 15 (39)
24 | case control studies/ (53391)
25 | 24 and 15 (67)
26 | Diagnosis, differential/ (240645)
27 | 26 and 15 (193)
28 | or/21,23,25,27 (283)
29 | 28 not 17 (168)
30 | limit 29 to human (168)
31 | limit 30 to english language (144)
32 | from 31 keep 1–144 (144)

## Literature search results for MRS

Ovid Technologies, Inc. Email Service

------------------------------

Search for: limit 30 to english language

Citations: 1–102

Database: Ovid MEDLINE(R) <1966 to January Week 4 2004>

Search Strategy:

1 | exp *alzheimer disease/di, ra (2639)
2 | exp Magnetic resonance spectroscopy/ or Magnetic Resonance Imaging/ (209607)
3 | and/1–2 (356)
4 | spectroscopy.mp. (51927)
5 | 1 and 4 (31)
6 | or/3,5 (359)
7 | limit 6 to yr=1995–2004 (259)
8 | 6 not 7 (100)
9 | magnetic resonance spectroscopy.tw. (7565)
10 | spectroscopy.tw. (51927)
11 | exp alzheimer disease/ (31261)
12 | exp "sensitivity and specificity"/ (151518)
13 | or/2,4,9–10 (235972)
14 | or/1,11 (31261)
15 | and/13–14 (1190)
16 | 12 and 15 (101)
17 | 6 or 16 (403)
18 | limit 17 to human (402)
19 | limit 18 to english language (351)
20 | discriminant analysis/ (3416)
21 | 20 and 15 (10)
22 | risk factors/ (229013)
23 | 22 and 15 (44)
24 | case control studies/ (53391)
25 | 24 and 15 (49)
26 | Diagnosis, differential/ (240645)
27 | 26 and 15 (158)
28 | or/21,23,25,27 (243)
29 | 28 not 17 (121)
30 | limit 29 to human (121)
31 | limit 30 to english language (102)
32 | from 31 keep 1–102 (102)

## Literature search results for MRI

Ovid Technologies, Inc. Email Service

------------------------------

Search for: from 31 [limit 30 to english language] keep 1–101

Citations: 1–101

Database: Ovid MEDLINE(R) <1966 to January Week 4 2004>

Search Strategy:

1 | exp *alzheimer disease/di, ra (2639)
2 | exp Magnetic Resonance Imaging/ (116854)
3 | and/1–2 (324)
4 | spectroscopy.mp. (51927)
5 | 1 and 4 (31)
6 | or/3,5 (345)
7 | limit 6 to yr=1995–2004 (261)
8 | 6 not 7 (84)
9 | (functional magnetic resonance imaging or functional MRI).tw. (3869)
10 | fMRI.tw. (3464)
11 | exp alzheimer disease/ (31261)
12 | exp "sensitivity and specificity"/ (151518)
13 | or/2,4,9–10 (166917)
14 | or/1,11 (31261)
15 | and/13–14 (1094)
16 | 12 and 15 (104)
17 | 6 or 16 (389)
18 | limit 17 to human (387)
19 | limit 18 to english language (340)
20 | discriminant analysis/ (3416)
21 | 20 and 15 (10)
22 | risk factors/ (229013)
23 | 22 and 15 (44)
24 | case control studies/ (53391)
25 | 24 and 15 (49)
26 | Diagnosis, differential/ (240645)
27 | 26 and 15 (155)
28 | or/21,23,25,27 (240)
29 | 28 not 17 (120)
30 | limit 29 to human (120)
31 | limit 30 to english language (101)
32 | from 31 keep 1–101 (101)
33 | from 32 keep 1–101 (101)