# Glossary

AAN: American Academy of Neurology
AChE-l: Cholinesterase inhibitor
AD: Alzheimer’s disease
AHRQ: Agency for Healthcare Research and Quality
ApoE4: Apolipoprotein E-4
Cho: Choline
CI: Cognitive impairment
cm: Centimeter(s)
CMS: Centers for Medicare and Medicaid Services
Cr: Creatine
CT: Computed tomography
DLB: Dementia with Lewy Bodies
EC: Entorhinal cortex
EPC: Evidence Practice Center
FDG: 2-Fluro 2-deoxy D-glucose
fMRI: Functional magnetic resonance imaging
FTD: Frontal temporal dementia
g: Gram(s)
HMPAO: Hexamethylpropylene amine oxime
LMRC: Lund-Manchester criteria
MCI: Mild cognitive impairment
MCAC: Medicare Coverage Advisory Committee
MeSH: Medical Subject Heading
METglu: Glucose metabolism
μg: Microgram(s)
mg: Milligram
ML: Myoinositol
ml: Milliliter(s)
mm^3^: Cubic millimeter
MMSE: Mini-mental State Examination
MRI: Magnetic Resonance Imaging
MND: Motor neuron disease
MRS: Magnetic resonance spectroscopy
MTL: Medial temporal lobe
mU: Milliunit(s)
NAA: N-acetylaspartate
ng: Nanogram(s)
NINCDS-ADRDA: National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Association
NR: not reported
PCG: Posterior cingulate gyrus
PD: Parkinson’s disease
Pdem: Parkinsonian dementia
PET: Positron emission tomography
QALY: Quality adjusted life year
rCBFi: Regional cerebral blood flow
RCT: Randomized controlled trials
ROI: Region of interest
SOW: Statement of work
SCI: Subjective cognitive impairment
SPECT: Single photon emission computed tomography
TA: Technology assessment
Tc HmPAO: Technetium-based HMPAO
VD: Vascular dementia
vs.: Versus
%: Percent