# Results

Overall, the horizon scan reports have identified 178 different genetic tests for 10 common cancer conditions. Our report lists 66 new genetic tests since the 2011 report, with the largest number of tests being utilized for breast cancer (Table 2). We identified 44 new tests through grey literature searches, and during peer review process, we added 22 new tests that are currently available in clinical use. The one-page description for these newly identified genetic tests for a variety of common solid tumors and hematological cancers cancer conditions can be found in Appendix A. Tests that were identified in our previous reports are listed in the Appendix Tables 1 and 2. One test (OvaSure) identified by our 2011 report has been withdrawn from the market. In addition, one test (PreGen Plus) identified as a test in clinical use in our 2006 report has also been withdrawn voluntarily from the market.

Of the 104 tests that were identified as tests in development in our 2006 report, only 21 tests matured to full clinical use in 2011. Recent Internet searches indicate that three additional tests are available for clinical uses (Appendix B). Among tests that were in development, four were excluded for the following reasons: one test (PyloriProbe) has been voluntarily withdrawn from the market, two tests that were identified as those used in the context of aspiration of cervical or breast specimens were excluded, and one test was excluded since it was identified as evaluating genetic material of infectious agent (digene High-Risk HPV HC2 DNA Test). The remaining 76 tests are currently being tracked as tests in development or in research.

Table 2 Genetic tests for cancer found between March 2011 and January 2013

Test Name | Germline (yes) | Purpose
| | Prognostic | Predictive | Diagnostic | Monitoring | Recurrence | Therapeutic management
Breast
Blue Print | | | | X | | | X
Breast cancer index | | X | | | | X
BreastOncPx™ | | | | | | | X
BreastNext™ | Yes | | X
Caris Target Now® for Breast Cancer^1^ | | | | | | | X
Cytochrome P450 2D6 genotyping | | X | | | | | X
Inform Dual ISH | | | | | | | X
Her-2 by FISH; Her-2 by ISH | | X | | | | | X
HER-2 neu (ERBB2) | | X | | | | | X
HERmark Breast Cancer Assay | | X | | | | | X
HER2 – DUAL ISH | | | | | | | X
MammaPrint | | X | | | | X | X
Mammostrat | | X | | | | X | X
MapQuant Dx Genomic grade test | | | | | | | X
OncoVue®^1^ | | X | X
OncoType DX™ | | X | | | | X | X
PAM50 breast Intrinsic Classifier | | X | | | | | X
Rotterdam Signature 76-Gene Panel | | X | | | | X
SYMPHONY™ Breast Cancer Profile | | X | | X | | X | X
TargetPrint | | | | | | | X
Colorectal
Caris Target Now® for Colorectal Cancer^1^ | | | | | | | X
ColoNext™ | Yes | | X
ColoPrint™ | | X | | X | | | X
ColoSeq™ | Yes | | X
GCC (GUCY2C) Blood Test | | | | X
Therascreen KRAS RGQ PCR | | | | X | | | X
PMS2 test | | | | X
Previstage™ GCC | | X
ResponseDx Colon® | | | | | | | X
Genitourinary
Onco FISH cervical | | X
UteroFISH | | | | | | | X
UroVysion FISH | | | | X | X
Hematologic
5q del, 7q del/-7 FISH test | | X | | | | | X
17 p deletion FISH | | X
Multiple myeloma panel FISH test | | X | | | | | X
MyPRS Plus | | X | | | | | X
Lung
ALK FISH | | | | X | | | X
Vysis ALK FISH test | | | | | | | X
Caris Target Now® for NSCLC^1^ | | | | | | | X
ResponseDx Lung ® | | | | | | | X
Ovarian
Caris Target Now® for Ovarian Surface Epithelial Cancer^1^ | | | | | | | X
PreOvar | Yes | | X
Prostate
Adenomatous polyposis coli (APC) | Yes | X
Glutathione-S-Transferase (GST-P1) | | X
Oncotype Dx Prostate | | | | | | | X
ProstaVysion | | X | | | | | X
Other^2^
Cobas® BRAF V600 mutation
BRAF gene mutation detection | Yes | | | | | | X
Caris Target Now® for Melanoma Cancer^1^ | | | | | | | X
MEN2 (RET) DNA sequencing test | Yes | | | X
miRInform™ Pancreas | | | | X
NeoSite Melanoma | | X
PIK3CA Oncogene mutation detection | | X | | | | | X
PDGFRA mutation analysis | | X | | | | | X
ResponseDx Melanoma® | | X | | | | | X
ResponseDx Gastric® | | X | | | | | X
RET gene sequencing | Yes | | | X
SDHB DNA sequencing test | Yes | X
1P, 19Q FISH | | X | | X
Multiple^3^
BROCA-Cancer Risk Panel | Yes | | X
CancerNext™ | Yes | | X
CancerType ID®^1^
EGFR FISH | | X
OVANEXT | Yes | | X
PANEXIA | Yes | | X
PTEN genetic analysis for cancer | | X | | X | | | X
5-FU sensitivity (DPYD, TYMS, and MTHFR) | | | | | | | X

1. One pager tests are not provided owing to the inadequate information available on company Web site

2. Other includes brain, liver, and upper gastrointestinal, respectively

3. Test used for multiple cancers including lung and brain