# Methods

## Genetic test

Our working definition of genetic tests includes genetic variations, panels of genetic markers, measurements of gene expression and transcription products, biochemical biomarkers, topographic genotyping, and cytogenetic tests. The terms “genetics” and “genomics” are often used interchangeably in the literature, and both can refer to tests for molecular or biochemical biomarkers, as well as cytogenetic and gene-based tests. In general, the genetic tests for cancer conditions have no specific names and are usually named after the disease/condition and/or by the gene and methodology of the specific genetic test. Thus, the name of a genetic test can vary from one laboratory to another. Therefore, the types of genetic tests in this report also include genomic, pharmacogenomic, proteomic, and other tests as reported by the individual manufacturers or laboratories that were identified through Internet searches. We summarized all genetic tests that provide diagnostic and prognostic information, monitor patient status, or detect disease recurrence.

## Eligibility criteria

### Inclusion criteria

We considered genetic tests that have applications in the 10 common solid tumors namely breast, lung, colorectal, pancreas, prostate, ovarian, upper gastrointestinal and liver, genitourinary, endocrine and hematologic cancers (leukemia, lymphoma). We included genetic tests that are already in clinical practice. We included genetic tests based on any one of the following selection criteria:

1. Genetic tests that have been cleared by FDA or pending clearance by FDA.
2. Genetic tests that are conducted in Clinical Laboratory Improvement Amendments (CLIA) certified labs and require a physician order, but may or may not have been cleared by FDA.
3. Genetic tests offered by Internet sites that specifically require a physician order.

The population of interest was adults with more applicability to the Medicare age group. We included genetic tests that are performed to aid in diagnosing, treating, predicting, and prognosticating, and monitoring cancer status or detecting cancer recurrence. Tests conducted for the same gene by multiple laboratories were included only once, except when a test varied explicitly in methodology or description.

### Exclusion criteria

We excluded tests that are performed for cancers that are exclusively early-onset and result in death before reaching adulthood and also excluded were tests marketed directly to consumers (direct-to-consumer genetic tests). We also excluded tests performed for the purpose of identifying noncancer conditions.

## Clinical Applications of Genetic Tests

For clinical applications of genetic tests that are covered in this report, we used the following categories to describe various applications:

1. Diagnostic: used to confirm or aid in the diagnosis of the particular disease.
2. Prognostic: information from the test can be used to determine or predict the aggressiveness of the disease or overall outcome of the disease at the time of initial diagnosis and prior to initiation of treatment.
3. Predictive: information from the test can be used to determine or predict the potential risk of eventually developing a disease or a disorder.
4. Recurrence: to detect disease recurrence in a patient who has already been diagnosed and treated for cancer.
5. Monitoring: test used to monitor tumor and/or patient response to treatment.
6. Therapeutic management: information can be used to determine therapeutic decisionmaking.

### Description of grey literature sources

The contents in this section were obtained directly from manufacturers’ Web sites or other commercial Web sites, and should not be considered as verified information.

1. Genetic Testing Registry (http://www.ncbi.nlm.nih.gov/gtr) is a Web site funded by the NIH with an overarching goal to advance public health and research into the genetic basis of health and disease. The NIH Genetic Testing Registry (GTR) is available since 2011 as a central location for voluntary genetic test information by providers. The current contents scope includes test’purpose, methodology, validity, evidence of the test’s usefulness, and laboratory contacts and credentials. This Web site also includes materials that were previously available at the GeneTests.org.
2. We searched Internet Web sites using the following algorithm. We first searched Google News (http://www.news.google.com) for the following: “gene, genetic, genomic, pharmacogenomic, epigenetic” OR “FDA + cleared genetic test.” The news items with their links were automatically deposited into an email system to generate daily email alerts. Periodically, we visited Web links listed in the news items weekly. We also visited the relevant laboratories that appeared in the news items to identify any new genetic tests. The Web links that identify potentially eligible tests are stored in a spreadsheet.
3. Commercial Web sites were screened to identify genetic tests that are available for routine clinical use. We also identified the Web pages of companies that supply tests such as Roche Diagnostics^®^, or major commercial laboratories in the United States, such as Quest Diagnostics^®^, and LabCorp^®^. A selected list of systematically queried laboratories and their Web sites can be found in Table 1. The Web sites of the major laboratories are visited once quarterly every year. For any potential genetic tests that were mentioned in these Web sites, we conducted focused Internet searches by including the specific test names to find more information, including other manufacturers, suggested uses, and press releases.
  Table 1 Selected list of Web sites that were reviewed to identify new genetic tests for cancers^*^
  Description | URL
  Quest Diagnostics^®^ | http://www.questdiagnostics.com/
  LabCorp^®^ | http://www.labcorp.com/
  Roche Diagnostics^®^ | http://www.roche-diagnostics.us/
  Athena Diagnostics, Inc | http://www.athenadiagnostics.com
  GeneDx | http://www.genedx.com
  Abbott Molecular Laboratories | http://www.abbottmolecular.com
  Google News | http://news.google.com
  FDA News | http://FDAnews.com
  Genelex Corporation | http://www.healthanddna.com/
  deCODE Genetics Inc. | http://www.decode.com/
  Medical Solutions Ltd. (Nottingham) | http://www.medical-solutions.co.uk/default.aspx
  DiagnoCure | http://www.diagnocure.com/en/index.php
  Epigenomics | http://www.epigenomics.com/
  Matritech, Inc. | http://www.matritech.com/
  Agendia | http://www.agendia.com
  Caris Life Sciences | http://www.molecularprofiling.com/
  Monogram Biosciences | http://www.monogrambio.com/
  Bostwick Laboratories | http://www.bostwicklaboratories.com/
  Arup Laboratories | http://www.aruplab.com/
  Wako Chemicals USA, Inc | http://www.wakousa.com/
  Veridex, LLC | http://www.veridex.com/
  Dako (formerly DakoCytomation) | http://www.dako.com/
  Clarient, Inc | http://www.clarientinc.com/
  Ambry Genetics | http://ambrygen.com/
  Prevention Genetics | http://www.preventiongenetics.com/
  Genomic Health | http://www.genomichealth.com/
  * Searches were not limited to these Web sites.
4. Other internet sites: At the direction of experts in the field of genetics, we included tests available at the following Web sites PHG Foundation (phgfoundation.org), EGAPP Reviews (egappreviews.org), and Association for Molecular Pathology (amp.org). To identify additional tests, searches were conducted in major academic /university Web sites such as Mayo Medical Laboratories, Baylor College of Medicine Medical Genetics Laboratories, GeneDx, and Emory Molecular Genetics Laboratory.
5. The two currently developing fields of pharmacogenetics (focuses on single genes) and pharmacogenomics (focuses on multiple genes) may provide insights into the inter-individual variability in drug responses. We identified genetic tests from the PharmGKB Web site (pharmgkb.org) maintained by Stanford University (4).

## Individual test summaries

Once the list of current genetic tests was identified, one-page summaries of each test were completed using data extracted from various sources, including laboratory Web sites and test manufacturer Web sites. Data included in these summaries are a more detailed description of the test and its clinical use. The “one-page summary” included the following items:

1. Test name: The majority of the clinically available genetic tests were identified either by the disease/ conditions or by the disease causing genes without any specific test name. Hence the gene names, protein, and disease/conditions served as the surrogate for the genetic testing identifier. When available, we recorded the specific test name.
2. Description: Included a brief summary of the genetic or genomic test and its association with the cancer condition.
3. Purpose: The clinical applications of genetic tests included primary or secondary prevention, diagnostic, prognostic, predictive, recurrence, monitoring, and therapeutic management.
4. Availability: Included a brief list of laboratories including commercial and academic laboratories in the U.S. and other countries.
5. Specimen: The specimen was utilized to evaluate the gene-disease condition, which included whole blood, serum, tumor tissue, etc.
6. Diseases: Included a list of disease conditions for which the genetic test was utilized
7. Clinical uses: Included genetic test applications in a clinical setting (e.g. routine use, investigational use, etc.).
8. Source: A list of additional sources that were typically consulted for information about the genetic test application.
9. Marker (Medline Search Terms: A PubMed search parameter; included the list of possible genetic test names, genes, and biomarkers that were used for Medline search strategy.
10. Organ (Medline Search Terms: A PubMed search parameter; included a list of specific organ(s) affected by the gene-disease association.
11. Exploratory PubMed search: The exploratory PubMed search included the name of the genetic or molecular marker, the disease, and the terms “cancer condition [MeSH®]”. For tests that use a panel of genetic or molecular markers, we used the brand name of the panel crossed with the search terms. All searches were repeated on 1/31/2013. For new tests added at the time of draft revision, all searches were repeated on 6/1/2013. These search strategies are exploratory and the number of citations returned is an estimate of the scientific literature available on each test-disease condition. However, this number is preliminary, and depending on the key questions to be addressed in a systematic review, the final yield of eligible citations may change based on search strategy and the application of specific screening criteria.

### Updating of the reports

The horizon scanning has been ongoing as a continuous process since 2005 and the identified tests are being continuously updated. We also assessed the relevance and availability of genetic tests identified overtime.