# Introduction

Recent scientific and technical advances in genomic testing have resulted in the rapid proliferation of lower cost and more efficient genomic technologies. (1;2) The number of available genetic tests that can be used in every day clinical practice is increasing, and the rapid dissemination of information regarding these tests is already occurring through the Internet. The genetic tests are used for a variety of purposes that may include screening, diagnosis, risk stratification, and therapeutic management. In addition, the genetic tests can be used as a clinical decisionmaking tool to aid disease monitoring and prognosis of patients.

Genetic tests are now increasingly being used for the screening and diagnosis of both cancer and noncancer conditions. Those for cancer differ from genetic tests for noncancer conditions in the relatively larger number of tests for somatic mutations. Somatic mutations are genetic mutations that occur in somatic cells after conception. As cancer develops, somatic mutations are common if growth regulators in the cell are damaged by toxins, radiation, random error in cell division, and other factors. Somatic mutations cannot be inherited and only affect the lineage of cells derived from mutated cells. In contrast, mutations in germ cells will affect all the cells in the body, and are often the result of acquired mutations from a parent.

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested that the Technology Assessment Program (TAP) of the Agency for Healthcare Research and Quality (AHRQ) conduct an update of the horizon scan of genetic tests for cancer conditions. AHRQ assigned this project to the Tufts Medical Center Evidence-based Practice Center (Contract Number: HHSA 290 2007 10055 I, Task Order #11). The current report presents an update of genetic tests for cancer conditions that were identified since the 2011 horizon scan report on Genetic Testing for Cancer.(3) Issues related to emerging genomic tests include lack of data on test performance, clinical validation, and impact on clinical outcomes. CMS would like the report and the accompanying one-page summaries to serve as a ready reference for their internal discussions in this area as well as the source for decisions on future topic generation for systematic reviews.

The main objective of this report is to provide a broad overview with sufficient information on each identified genetic test, and to provide a preliminary estimate on the amount of published literature available on each genetic test. This report is not meant to be an in-depth review of each test. The contents in this report reflect the data of genetic tests that were obtained from manufacturers’ or other commercial Web sites, and should not be construed as verified information or definitive clinical evidence or as recommendations for their routine clinical use.