# Discussion

We performed Internet-based grey literature searches and added a total of 66 new genetic tests available for clinical use in cancer conditions since our 2011 report. Of these, 44 new genetic tests were identified through grey literature searches alone. The remaining 22 tests were identified by peer and public reviewers. A total of 24 tests matured to clinical use of the 104 tests “in development” in our 2006 report. Recent grey literature searches indicate that the largest numbers of new tests were found in the breast cancer category to aid in prognosis or predict response to therapies as well as to individualize therapeutic management. Most of the information for each of the genetic tests was gathered from various public and proprietary Web sites. The laboratories offering genetic testing services provided most of the information on the description of the gene involved with the disease. We searched sites that were identified from our prior horizon scan reports (previous Genetic Testing for Cancer Conditions reports) and many other sites identified through Google News searches. In terms of tests that were in development, only few biomarkers (22%) made it to the clinical application stage.

Potential limitations of our report include lack of empirical structure providing guidance on how to conduct optimal grey literature searches of the Internet. The following are caveats to our grey literature searches. Internet searches are not strictly reproducible. Periodically we stored Web links along with access dates. However, for searches conducted within a reasonably short time period, the Web pages will be more or less the same. To overcome such limitations related to Internet searches conducted in Google, we supplemented with periodic review of Web sites of major companies that manufacture genetic and molecular tests, and by searching the FDA Web site. The attempt to horizon scan genomic testing through Web searching has been applied by at least one other group that focuses on emerging genetic tests with continuous updating (http://www.hugenavigator.net/GAPPKB/topicFinder.do).(5) We did not contact companies and, this process limits our ability to identify a test with multiple commercial names (for example, a test that has been licensed from one company to another company, but carries a different commercial name for the same test) or if changes are made to a test that retains the same name (for example, when additional single-nucleotide polymorphisms are added to a test). Future grey literature searches can explore the possible engagement of relevant stakeholders in this field to identify potentially useful Web sites.

Our report indicates that there has been an increase in the number of genetic tests available for clinical use, and we limited emerging genetic tests. Many genetic and molecular markers and panels are being associated with cancer conditions. We have selected those that are available for clinical applications in screening, diagnosis, prognosis, prediction, disease recurrence, therapeutic management, or patient monitoring as tests for cancer conditions. In addition to grey literature searches, our discussion with local experts helped us to identify this list of genetic tests. The tests identified from prior reports have been utilized to generate topics for conducting systematic reviews for various cancer conditions.(6–8)

This report of horizon scan for genetic tests for cancer conditions, with biannual updates, adds important information on emerging tests. The NIH registry was launched in February 2012.(9) Currently, NIH registry is fully effective and future readers are directed to obtain information on emerging genetic tests from their Web site (http://www.ncbi.nlm.nih.gov/gtr/).(10) The current report is a valuable source of genetic tests that are in clinical use for common cancer conditions with specific applicability to older adults. Genetic testing is a rapidly emerging field with the potential to dramatically influence clinical decision-making. Health care providers, patients, payers, decision-makers, and consumers can benefit from staying abreast of newly-released tests.