# Genetic Tests For Cancer From Prior Horizon Scan Reports

Table B-1 Genetic tests for cancer found between January, 2006 and February 2011

Test Name | Germline (Y) | Purpose
| | Prognostic / Predictive | Diagnostic | Monitoring | Recurrence | Therapeutic management
Breast
Breast Profile | | | | | | x
deCODE BreastCancer™ | | X | X
GeneSearch™ BLN Assay | | X | X
Her2 Neu Overexpression | | | | | | X
Her2 Pro™ | | | X | | | X
MammaPrint® | | X | X
SPOT-Light ®HER2 CISH Kit | | | | | | X
Tamoxitest™ | | | | | | X
TOP2A FISH pharmDx™ Kit | | X | | X
Colorectal
BRAF mutation | Y | X | X | | | X
ColonSentry™
Colopath®/ColorectAlert™ | | | X
Cytokeratin 20(CK 20) | | | X
KRAS Mutation Analysis | | X
Oncotype DX® colon cancer assay | | | | | X
Septin-9 DNA methylation biomarker | | | X
UGT1A1 Molecular Assay™ | | | | | | X
Genitourinary
ImmunoCyt™/uCyt+™ | | | | X
NMP22®BladderChek® | | | X
Hematologic
G6PD | | | | | | X
Heme Profile | | X
JAK2 | | | X | | | X
KIT Asp816Val Mutation Analysis | | | X | | | X
Lung
CellCorrect KvA-40 Lab® Kit | | | X
EGFR Mutation Analysis | Y | | | | | X
ELSA-CYFRA 21-1 | | X | X
ERCC1 | Y | | | | | X
KRAS Mutation Analysis | | X | | | | X
MESOMARK® | | | X | | | X
Ovarian
OVA1™ | | X
OvaCheck™ | | | X
OvaSure™ | | | X
Prostate
Bayer Immuno 1™ Complexed PSA | | | X | X
deCODE Prostate Cancer | | | X
Hybritech Tandem-R free PSA test | | | X
Progensa® PCA3 Assay | | X | X | | | X
Prostate-63 | | | X
uPM3™ test; PCA3Plus™ test | | X | X
Other^**^
DakoCytomation’s c-Kit (9.7) pharmDx™ | | | X | | | X
LBA®AFP-L3
MGMT methylation testing | | | | | | X
Multiple^***^
CellSearch® | | X | | X | X
CupPrint | | | X
DPD deficiency | | | | | | X
EGFR™ assay | | | | | | X
miRview™ | | | X
Pathwork® Tissue of Origin test | | | X
PI3K | | X
TheraGuide™ | | | | | | X
Tumor Profile | | X

** Other includes brain, liver, and upper gastrointestinal, respectively

*** Tests used for multiple cancers including breast, colorectal, lung, ovarian, prostate

Table B-2 Genetic tests for cancer found until December, 2005

NAME | Germline (y) | Breast | Prostate | Lung | Colorectal | Pancreas | Ovarian | Esophagus | Liver | Lymphoma | Leukemia
Acid phosphatase, total and prostatic | | | x
Adrenocorticotropic hormone | | | | x | | x
Alpha fetoprotein | | | | x | x | x | | | x
AML1/ETO translocation | | | | | | | | | | | x
B-cell gene rearrangement | | | | | | | | | | x
BCL-1/JH gene rearrangement | | | | | | | | | | x
BCL-2 translocation | | | | | | | | | | x
BCR/ABL gene rearrangement | | | | | | | | | | | x
Beta human chorionic gonadotropin | | | | x | | x | x | | x
Beta-2 microglobulin | | | | | | | | | | x
Bladder tumor antigen
BRCA Analysis | Y | x | | | | x | x
Calcitonin
Cancer antigen 125 | | x | | x | x | x | x
Cancer antigen 15-3 | | x
Cancer antigen 19-9 | | | | | x | x | | | x
Cancer antigen 27.29 | | x | | x | | x | x | | x
Carcinoembryonic antigen | | x | | x | x | x | x
Cathepsin D | | x
CBFB/MYH11 fusion protein | | | | | | | | | | | x
CD 117, c-kit
CD 20 | | | | | | | | | | x
CD 25 | | | | | | | | | | x
CD 33 | | | | | | | | | | | x
CD 52 | | | | | | | | | | | x
Chromosome 18q assay | | | | | x
Colaris | | | | | x
Colaris AP | | | | | x
Cyclin-D1 | Y | | | | | | | | | x
E-cadherin | Y | | x
Epidermal growth factor receptor | | x | x | x | x
Estrogen/progesterone receptor | | x
Fecal globin | | | | | x
FLT 3 mutation | | | | | | | | | | | x
HER-2/neu | | x | | | | | x
5-HIAA
Human papillomavius hybrid capture
IgVH mutation analysis | | | | | | | | | | | x
Immunocyt
Kappa/lambda light chain | | | | | | | | | | x
LAP | | | | | | x
Lipid associated sialic acid | | x | | x | x | x | x | | x | x | x
Melaris | | | | | | x
MIB-1 antibody | | x | | | | | | | | x
Micrometastasis detection | | x
Microsatellite instability | | | | | x
MLH1, MSH2, MSH6 mutations | Y | | | | x
Neuron specific enolase | | | | x | | x
Nuclear matrix proteins
Oncotype Dx | | x
p53 tumor suppressor gene | Y | x | x | | x
PML/RARA translocation | | | | | | | | | | | x
PreGen-26 | | | | | x
PreGen-Plus | | | | | x
Prostate-specific antigen | | | x
T-cell recepter gene rearrangment | | | | | | | | | | x
TEL/AML1 gene fusion | | | | | | | | | | | x
Thyroglobulin
Tumor antigen 90 immune complex
Urokinase plasminogen activator | | x
Urovysion
ZAP-70 | | | | | | | | | | | x

Table B-3 Tests that matured to clinical use since 2006

Name | Breast | Prostate | Lung | Colorectal | Pancreas | Ovarian | Esophagus | Liver | Lymphoma | Leukemia | Other
AFP-L3 | | | | | | | | x
APC | | x
BladderChek | | | | | | | | | | | x
CeMines CellCorrect Lab | | | x
c-Kit pharmDx | | | | | | | | | | | x
Colorectalert | | | | x
cPSA | | x
CupPrint | | | | | | | | | | | x
Cyfra 21-1 | | | x
DNA methylation (oncomethylome) | | x | x | | | x | | | | | x
DNA methylation (second code) | | x | x | x
EGFR | | | x
Immunocyt/ uCyt | | | | | | | | | | | x
Iressa test (EGFR mutation analysis) | | | x
K-ras | | | x | x
MammaPrint | x
MESOMARK | | | | | | | | | | | x
MGMT | | | | x
NMP22 | | | | | | | | | | | x
Ovacheck | | | | | | x
OncoVue | x
Prostate 63 | | x
TUO test | | | | | | | | | | | x
uPM3 | | x