# One-page summaries of the genetic tests for cancers

## BREAST CANCER

### Gene Test Information: Breast cancer index, breast cancer

Test Name: Breast cancer index

Description: BioTheranostics Breast Cancer Index^SM^ (BCI) is a prognostic biomarker that provides quantitative assessment of the likelihood of distant recurrence in patients diagnosed with estrogen receptor-positive, lymph node-negative breast cancer. In development and validation studies, BCI stratified ~50% of tamoxifen treated ER+, node-negative breast cancer patients into a low risk group for 10-year distant recurrence.

Purpose: Prognostic and Recurrence

Availability: Bio Theranostics

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue block

Methodology: BCI is a molecular assay developed from the combination of two indices: HOXB13:IL17BR and Five cell cycle-associate gene index that assesses tumour grade.

Diseases: breast cancer

Clinical Uses: BioTheranostics Breast Cancer Index^SM^ (BCI) is a prognostic biomarker that provides quantitative assessment of the likelihood of distant recurrence in patients diagnosed with estrogen receptor-positive, lymph node-negative breast cancer.

Sources: www.biotheranostics.com

Marker (Medline Search): HOXB13 OR IL17BR

Organ (Medline Search): breast

Medline Searches: (HOXB13[All Fields] OR IL17BR[All Fields]) AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms" [All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=31

FDA approved: No

### Gene Test Information: BluePrint, breast cancer

Test Name: BluePrint® Molecular Subtyping Signature

Description: BluePrint is an 80-gene profile that classifies breast cancer into molecular subtypes. The profile separates tumors into Basal-type, Luminal-type and ERBB2-type subgroups by measuring the functionality of downstream genes for each of these molecular pathways to inform the physician of the potential effect of adjuvant therapy.

Purpose: Diagnostic, Therapeutic management of breast cancer

Availability: Agendia

Specimen: Formalin fixed paraffin-embedded, fresh or frozen breast tumor tissue

Methodology: Genomic signature by microarray-based RNA gene expression

Diseases: breast cancer

Clinical Uses: Blueprint® provides information on the sub-classification of the tumor which guides the choice of therapies and combinations of therapies.

Sources: www.agendia.com

Marker (Medline Search): BluePrint

Organ (Medline Search): breast

Medline Searches: BluePrint[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms" [All Fields]) OR "breast neoplasms" [All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=22

FDA approved: No

### Gene Test Information: BreastNext™

Test Name: BreastNext™

Description: BreastNext™utilizes next generation sequencing to offer a comprehensive testing panel for hereditary breast and/or ovarian cancer and targets detection of mutations in 14 genes (ATM, BARD1, BRIP1, CDH1, CHEK2,MRE11A, MUTYH, NBN, PALB2, PTEN, RAD50, RAD51C, STK11 and TP53), excluding BRCA1 and BRCA2. Gross deletion/duplication analysis is performed for all 14 genes.

Purpose: Predictive

Availability: Ambry genetics

Specimen: Blood, DNA, or Saliva

Methodology: gene sequencing, deletion/duplication analysis

Diseases: Breast cancer; ovarian cancer

Clinical Uses: Mutations in BRCA1 and BRCA2 explain hereditary breast cancer occurrence ~25–50% of the time, additional genes associated with hereditary breast cancer are emerging. Studies suggest that mutations in the genes on the BreastNext™ panel may confer an estimated 25–70% lifetime risk for breast cancer.

Sources: www.ambrygen.com

Marker (Medline Search): (ATM OR BARD1 OR BRIP1 OR CDH1 OR CHEK2 ORMRE11A OR MUTYH OR NBN OR PALB2 OR PTEN OR RAD50 OR RAD51C OR STK11 OR TP53)

Organ (Medline Search): breast OR ovarian cancer

Medline Searches: (("atm"[All Fields]) OR BARD1[All Fields] OR BRIP1[All Fields] OR CDH1[All Fields] OR CHEK2[All Fields] OR muty[All Fields] OR NBN[All Fields] OR PALB2[All Fields] OR pten[All Fields] OR RAD50[All Fields] OR RAD51C[All Fields] OR STK11[All Fields] OR TP53[All Fields]) AND (("breast neoplasms"[MeSH Terms] OR ("breast" [All Fields] AND "neoplasms" [All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields]) OR ("ovarian neoplasms"[MeSH Terms] OR ("ovarian"[All Fields] AND "neoplasms"[All Fields]) OR "ovarian neoplasms"[All Fields] OR ("ovarian"[All Fields] AND "cancer"[All Fields]) OR "ovarian cancer"[All Fields])) AND "humans"[MeSH Terms]

Medline hits=3202

FDA approved: No

### Gene Test Information: Cytochrome P450 2D6, breast cancer

Test Name: Cytochrome P450 2D6 genotyping

Description: The cytochrome (P450) enzyme catalyse the oxidation of many drugs and chemicals. Individual differences of cytochrome P450 activity can result in the total absence of the metabolism of certain drugs to ultrafast metabolism and can also lead to adverse drug reactions or a lack of therapeutic effect under standard therapy conditions. Specific variants in this gene also influence the metabolism of the breast cancer drug, tamoxifen, in postmenopausal women.

Purpose: Predictive and Therapeutic management

Availability: Labcorp

Specimen: Whole blood

Methodology: Polymerase chain reaction (PCR) and allele-specific primer extension. This analysis includes identification of the following CYP2D6 alleles:*1, *2, *3, *4, *5, *6, *7, *8, *9, *10, *11, *12, *14, *15, *17, *41, *1XN, *2XN, *4XN, *10XN, *17XN, *41XN.

Diseases: Breast cancer

Clinical Uses: Genetic polymorphism of CYP2D6 could be used to predict the altered enzyme activity and address the potential effects of metabolized drugs.

Sources: www.labcorp.com

Marker (Medline Search): cytochrome P450 2D6 and breast cancer

Organ (Medline Search): breast

Medline Searches: ("cytochrome p-450 cyp2d6"[MeSH Terms] OR ("cytochrome"[All Fields] AND "p-450"[All Fields] AND "cyp2d6"[All Fields]) OR "cytochrome p-450 cyp2d6"[All Fields] OR ("cytochrome"[All Fields] AND "p450"[All Fields] AND "2d6"[All Fields]) OR "cytochrome p450 2d6"[All Fields]) AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hit: 247

FDA approved: No

### Gene Test Information: Dual ISH, breast

Test Name: Inform Dual ISH

Description: The Inform Dual ISH test allows lab personnel to count the number of copies of HER2 genes on chromosome 17 in a small sample of the breast tumor. Copies of the HER2 gene appear black and copies of chromosome 17 appear red. Patients with more than the normal number of copies of the HER2 gene are considered candidates for Herceptin therapy.

Purpose: Therapeutic management

Availability: Ventana Medical Systems

Specimen: Tumour tissue

Methodology: Dual in-situ hybridization (ISH)

Diseases: Breast cancer

Clinical Uses: A new genetic test that will help health care professionals determine if women with breast cancer are HER2-positive and, therefore, candidates for Herceptin (trastuzumab), a commonly used breast cancer treatment

Sources: www.fda.gov

Marker (Medline Search): HER-2 chromosome 17

Organ (Medline Search): breast

Medline Searches: (("genes, erbb-2"[MeSH Terms] OR ("genes"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 genes"[All Fields] OR "her 2 neu"[All Fields]) AND (("chromosomes"[MeSH Terms] OR "chromosomes"[All Fields] OR "chromosomal"[All Fields]) AND 17[All Fields])) AND ("breast neoplasms"[MeSH Terms] OR ("breast" [All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast" [All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=174

FDA approved: Yes

### Gene Test Information: Her-2 by FISH; Her-2 by ISH, breast

Test Name: Her-2 by FISH; Her-2 by ISH

Description: HER 2 amplification (positive) predicts resistance to standard chemotherapy. HER2 amplification also predicts response to anthracycline agents (adriamycin) in high dose chemotherapy, and response to the humanized monoclonal antibody. A negative test is indicated by a ratio of less than 1.8, equivocal test is indicated by a ratio from 1.8 to 2.2, and a positive test is indicated by a ratio greater than 2.2.

Purpose: Prognostic and therapeutic management

Availability: PathVysion, a registered trademark of Vysis Inc

Specimen: Tumour tissue

Methodology: Fluorescence in situ Hybridization; In situ Hybridization

Diseases: Breast cancer

Clinical Uses: HER-2 Fluorescence in situ Hybridization test are often used in advanced breast cancer to assess prognosis and therapeutic choices

Sources: www.labcorp.com/wps/portal/; www.abbottmolecular.com

Marker (Medline Search): HER-2 AND Fluorescence in situ Hybridization test

Organ (Medline Search): Breast

Medline Searches: ("genes, erbb-2"[MeSH Terms] OR ("genes"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 genes"[All Fields] OR "her 2 neu"[All Fields]) AND ("receptor, erbb-2"[MeSH Terms] OR ("receptor"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 receptor"[All Fields] OR "erbb2"[All Fields] OR "genes, erbb-2"[MeSH Terms] OR ("genes"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 genes"[All Fields]) AND (("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("research design"[MeSH Terms] OR ("research"[All Fields] AND "design"[All Fields]) OR "research design"[All Fields] OR "test"[All Fields]) AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields]))

Medline hits=124

FDA approved: Not reported

### Gene Test Information: HER-2 neu (ERBB2), breast

Test Name: HER-2 neu (ERBB2)

Description: HER 2 amplification (positive) predicts resistance to standard chemotherapy. HER2 amplification also predicts response to anthracycline agents (adriamycin) in high dose chemotherapy, and response to the humanized monoclonal antibody.

Purpose: Prognostic and therapeutic management.

Availability: BayCare Laboratories

Specimen: Tumour tissue

Methodology: Fluorescence in situ Hybridization

Diseases: Breast cancer

Clinical Uses: HER-2 neu (ERBB2) is used to help determine prognosis and therapeutic choices for invasive breast cancer.

Sources: www.baycare.org/laboratories

Marker (Medline Search): HER-2 neu (ERBB2) Fluorescence in situ Hybridization test

Organ (Medline Search): Breast

Medline Searches: ("genes, erbb-2"[MeSH Terms] OR ("genes"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 genes"[All Fields] OR "her 2 neu"[All Fields]) AND ("receptor, erbb-2"[MeSH Terms] OR ("receptor"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 receptor"[All Fields] OR "erbb2"[All Fields] OR "genes, erbb-2" [MeSH Terms] OR ("genes"[All Fields] AND "erbb-2"[All Fields]) OR "erbb-2 genes"[All Fields]) AND (("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ" [All Fields] AND "hybridization" [All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("research design"[MeSH Terms] OR ("research"[All Fields] AND "design"[All Fields]) OR "research design"[All Fields] OR "test"[All Fields]) AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms" [All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer" [All Fields]))

Medline hits=124

FDA approved: Yes

### Gene Test Information: HERmark, Breast Cancer

Test Name: HERmark Breast Cancer Assay

Description: HERmark Breast Cancer Assay is used to help determine prognosis and therapeutic choices for metastatic breast cancer. Clinical Practice Guidelines recommend determining HER2 status in patients with all invasive breast cancer, but caution that current HER2 testing methods such as central immunohistochemistry and Fluorescence in situ Hybridization test may be inaccurate in approximately 20% of cases. According to the HERmark Web site, their method precisely quantifies HER2 total protein and HER2 homodimer levels in formalin-fixed, paraffin-embedded tissue sections and outperformed Fluorescence in situ Hybridization at determining patient outcomes in patients with metastatic breast cancer.

Purpose: Prognostic and therapeutic management

Availability: HERmark®, a registered trademark of biosciences monogram

Specimen: Formalin-fixed, paraffin-embedded tissue sections

Methodology: Not reported

Diseases: breast cancer

Clinical Uses: prognosis and therapeutic choices

Sources: www.labcorp.com; www.monogrambio.com

Marker (Medline Search): HERmark

Organ (Medline Search): Breast

Medline Searches: HERmark[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits =7

FDA approved: Not reported

### Gene Test Information: HER2 DUAL ISH, Breast Cancer

Test Name: HER2 – DUAL ISH

Description: HER 2 overexpression occurs in 18–20% of breast cancers and indicates resistance to standard chemotherapy. Patients with HER2 positive breast cancer can benefit from Trastuzumab, a humanized monoclonal antibody against the extracellular domain of HER2. Therefore, demonstration of HER2 gene amplification and/or protein overexpression in the tumor can aid in selecting patients for trastuzumab therapy. Chromogenic in situ hybridization signals do not fade over time allowing tissue samples to be archived and reviewed later.

Purpose: Therapeutic management (adjunctive with HER IHC and HER FISH)

Availability: Labcorp

Specimen: Formalin-fixed Tumor tissue of breast

Methodology: Chromogenic in situ hybridization (ISH)

Diseases: Breast Cancer

Clinical Uses: Evaluation aids in identifying breast cancer patients with HER2 overexpression and in selecting patients for trastuzumab therapy.

Sources: www.labcorp.com/integratedoncology

Marker (Medline Search): HER2 AND Chromogenic in situ hybridization

Organ (Medline Search): Breast cancer

Medline Searches: HER2[All Fields] AND (dual[All Fields] AND ("in situ hybridization"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields]) OR "in situ hybridization"[All Fields])) AND ("breast neoplasms" [MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast" [All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits = 53

FDA approved: Yes

### Gene Test Information: MammaPrint, breast cancer

Test Name: MammaPrint

Description: MammaPrint a 70-gene profile that classifies breast cancer into Low Risk or High Risk of recurrence, by measuring genes representative of all the pathways of cancer metastases which were selected for their predictive relationship to 10-year recurrence probability. MammaPrint is indicated for women who have stage I or II breast cancer, are lymph node positive or negative, are ER-positive or negative and tumor size of less than five centimeters.

Purpose: Prognosis, recurrence, predictive, and therapeutic management of breast cancer

Availability: Agendia.com

Specimen: Formalin fixed paraffin-embedded, fresh or frozen breast tumor tissue

Methodology: Genomic signature by microarray-based RNA gene expression

Diseases: Breast cancer

Clinical Uses: MammaPrint determines if the patient is a candidate for chemotherapy..

Sources: www.agendia.com

Marker: MammaPrint

Organ: Breast

Medline Searches: MammaPrint[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=74

FDA approved: Yes

### Gene Test Information: Mammostrat, breast cancer

Test Name: Mammostrat

Description: Mammostrat is a novel test for estimating the risk for recurrence in hormone-receptor positive, early stage breast cancer that is independent of proliferation and grade. Five biomarkers are combined with a defined mathematical algorithm resulting in a risk index. Mammostrat is clinically validated and has been studied on more than 4,500 total patients in numerous independent cohorts that include the NSABP B14 and B20 trials.

Purpose: Prognostic, recurrence, and therapeutic management

Availability: Clarinet

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue block

Methodology: Not reported

Diseases: Breast cancer

Clinical Uses: Clinicians and patients are faced with difficult choices as to whether to add toxic adjuvant chemotherapy in addition to standard endocrine treatment. Mammostrat may help clinicians understand the inherent aggressiveness of the tumor and the likelihood of tumor recurrence.

Sources: www.clarientinc.com

Marker (Medline Search): Mammostrat

Organ (Medline Search): breast

Medline Searches: Mammostrat[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast" [All Fields] AND "neoplasms" [All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=3

FDA approved: No

### Gene Test Information: MapQuant Dx Genomic grade test, breast cancer

Test Name: MapQuant Dx Genomic grade test

Description: Tumor grade is a decision factor in most national and international guidelines to breast cancer treatment. It is generally recommended to treat high-grade “grade 3” breast carcinoma with chemo therapy because they are chemosensitive and will often recur otherwise. By contrast, most low-grade “grade 1” tumors should not be treated with chemotherapy because they have a good prognosis and are often chemo-insensitive. A key clinical issue is how to treat the 50% of breast cancers tested today as uncertain/Intermediate “grade 2” by current methods. MapQuant DX genomic grade test directly measures the expression of 97 genes that best characterize high-grade vs. Low-grade tumors. It can resolve these grade 2 tumors into either grade 1 or grade 3 tumors in 80% of cases.

Purpose: Therapeutic management of breast cancer

Availability: IPSOGEN

Specimen: Blood

Methodology: Not reported

Diseases: Breast cancer

Clinical Uses: This test may be useful when tumor grade information can be decisive for prescribing chemotherapy.

Sources: www.ipsogen.com

Marker (Medline Search): MapQuant

Organ (Medline Search): breast

Medline Searches: MapQuant[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits =4

FDA approved: No

### Gene Test Information: OncoType DX, breast cancer

Test Name: OncoType DX TM

Description: Oncotype that analyses the patterns of 21 genes is being applied as a quantification tool for likelihood of breast cancer recurrence within 10 years of newly diagnosed, stage I or II, lymph node-negative, hormone receptor-positive breast cancer in women who will be treated with tamoxifen.

Purpose: Prognosis, recurrence, and therapeutic management

Availability: Genomic Health

Specimen: Paraffin-preserved tissue

Methodology: RT-qPCR

Diseases: Breast cancer

Clinical Uses: Oncotype is being applied as a quantification tool for likelihood of breast cancer recurrence in 10 years in women with newly diagnosed breast cancer. It is also intended to assist in making decisions regarding adjuvant chemotherapy based on recurrence likelihood.

Sources: www.genomichealth.com

Marker: OncoType DX

Organ: Breast

Medline Searches: OncoType[All Fields] AND DX[All Fields] AND ("breast neoplasms" [MeSH Terms] OR ("breast" [All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=118

FDA approved: No

### Gene Test Information: BreastOncPx™, breast cancer

Test Name: BreastOncPx™ (Breast Cancer Prognosis Gene Expression Assay)

Description: BreastOncPx™, a 14-gene signature assay provides prognostics information for lymph node-negative (N-), estrogen receptor-positive (ER+) breast cancer patients and is associated with risk of distant metastasis. It helps identify higher-risk patients who might benefit from additional therapy.

Purpose: Therapeutic management

Availability: US Labs

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue block

Methodology: 14-gene signature assay

Diseases: Breast cancer

Clinical Uses: BreastOncPx™ that provides prognostic information to aid identifying higher-risk patients who might benefit from additional therapy.

Sources: www.uslabs.net

Marker (Medline Search): BreastOncPx™ and breast cancer

Organ (Medline Search): breast

Medline Searches: mark[All Fields] AND ("breast neoplasms" [MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits =476

FDA approved: No

### Gene Test Information: PAM50 breast Intrinsic Classifier, breast cancer

Test Name: PAM50 breast Intrinsic Classifier

Description: PAM50 Breast Cancer Intrinsic Classifier examining 50 genes and sorts breast cancer into four subtypes. Each subtype responds differently to standard therapies, and knowing the subtype allows doctors to tailor treatment for each patient.

Purpose: Prognostic and therapeutic management

Availability: University of Utah

Specimen: Tumor tissue

Methodology: RT-qPCR

Diseases: Breast cancer

Clinical Uses: PAM50 assay can aid profiling for both prognosis and prediction of benefit from adjuvant tamoxifen and has been found superior to immunohistochemistry.

Sources: www.hci.utah.edu

Marker (Medline Search): PAM50 breast Intrinsic Classifier

Organ (Medline Search): breast cancer

Medline Searches: PAM50[All Fields] AND ("breast"[MeSH Terms] OR "breast"[All Fields]) AND Intrinsic[All Fields] AND Classifier[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=3

FDA approved: No

### Gene Test Information: Rotterdam Signature, breast cancer

Test Name: Rotterdam Signature 76-Gene Panel

Description: The Rotterdam Signature test is a 76-gene expression assay. Sixty genes are intended to evaluate estrogen-receptor positive samples and 16 genes to evaluate estrogen-receptor negative samples. In a validation study that tested the signature on samples from 148 women, 50 fell into the low-risk group and 98 into the high-risk group. The test had 88% specificity and 39% sensitivity for the low-risk group, with a hazard ratio for distant relapse within 5 years of 5.74 comparing the high-risk group to the low-risk group.

Purpose: Prognostic, predictive, and recurrence

Availability: Veridex, LLC

Specimen: Tumor tissue

Methodology: Not reported

Diseases: breast cancer

Clinical Uses: Identifies women at high and low risk of disease recurrence.

Sources: www.hci.utah.edu

Marker (Medline Search): Rotterdam signature

Organ (Medline Search): breast cancer

Medline Searches: rotterdam[All Fields] AND ("Signature"[Journal] OR "signature"[All Fields]) AND ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms" [All Fields] OR ("breast" [All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=7

FDA approved: No

### Gene Test Information: SYMPHONY™, Breast Cancer

Test Name: SYMPHONY™ Breast Cancer Profile

Description: SYMPHONY™ provides complete tumor profiling and is used to support therapeutic choices for breast cancer. SYMPHONY includes four assays to support breast cancer treatment decisions: MammaPrint® determines the risk of recurrence. BluePrint™ determines molecular subtypes and TargetPrint® determines estrogen receptor (ER), progesterone receptor (PR), and HER2 status. TheraPrint™ identifies alternative types of therapy for metastatic disease.

Purpose: Diagnostic, prognostic, recurrence, and therapeutic management

Availability: Agendia

Specimen: formalin-fixed, paraffin-embedded tissue sections

Methodology: Panel of several genomic tests; microarray-based RNA gene expression methodology

Diseases: breast cancer

Clinical Uses: SYMPHONY provides genomic information assisting with therapeutic decisions even for cases that have been otherwise classified as indeterminate, such as grade 2, small tumors, HER2 and/or lymph node positive. MammaPrint® determines if the patient is a candidate for chemotherapy. TargetPrint® determines if the patient is a candidate for hormonal therapy. BluePrint® provides information on the sub-classification of the tumor which guides the choice of therapies and combinations of therapies. TheraPrint® identifies alternative types of therapy for metastatic disease.

Sources: www.agendia.com

Marker (Medline search): Mammaprint AND BluePrint AND TargetPrint AND TheraPrint

Organ (Medline search): breast cancer

Medline Searches: Mammaprint[Title] AND BluePrint[Title] AND TargetPrint[Title] AND breast[Title] AND cancer[Title]

Medline hits=1

FDA approved: No

### Gene Test Information: TargetPrint, breast cancer

Test Name: TargetPrint®, ER/PR/HER2 Expression Assay

Description: TargetPrint is a microarray-based gene expression test which offers a quantitative assessment of the patient’s level of estrogen receptor (ER), progesterone receptor (PR) and HER2/neu overexpression within her breast cancer. TargetPrint is offered in conjunction with MammaPrint to provide the physician an even more complete basis for treatment decisions.

Purpose: Therapeutic management

Availability: Agendia

Specimen: Formalin fixed paraffin-embedded, fresh or frozen breast tumor tissue

Methodology: Panel of three separate single gene readouts by microarray-based RNA gene expression

Diseases: Breast cancer

Clinical Uses: TargetPrint delivers an added benefit to the diagnostic process. Immunohistochemistry provides a semi-quantitative positive or negative result, whereas the gene expression result provided by TargetPrint allows physicians to integrate the absolute level of ER, PR and HER2 gene expression into treatment planning. TargetPrint determines if the patient is a candidate for hormonal therapy.

Sources: www.agendia.com

Marker (Medline Search): TargetPrint and breast cancer

Organ (Medline Search): breast

Medline Searches: TargetPrint[All Fields] AND ("breast neoplasms"[MeSH Terms] OR ("breast" [All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])

Medline hits=4

FDA approved: No

## COLORECTAL CANCER

### Gene Test Information: ColoNext™

Test Name: ColoNext™

Description: ColoNext™utilizes next generation sequencing to offer a comprehensive testing panel for hereditary colon cancer and targets detection of mutations in 14 genes (APC, BMPR1A, CDH1, CHEK2, EPCAM, MLH1, MSH2, MSH6, MUTYH, PMS2, PTEN, SMAD4, STK11, and TP53). Gross deletion/duplication analysis is performed for all 14 genes.

Purpose: Predictive

Availability: Ambry genetics

Specimen: Blood, DNA, or Saliva

Methodology: gene sequencing, deletion/duplication analysis

Diseases: Colon Cancer

Clinical Uses: ColoNext™ is a next-generation cancer panel that simultaneously analyzes selected genes associated with a wide range of cancers. While mutations in each gene on this panel may be individually rare, they may collectively account for a significant amount of hereditary cancer susceptibility.

Sources: www.ambrygen.com/tests/colonext

Marker (Medline Search): (APC OR BMPR1A OR CDH1 OR CHEK2 OR EPCAM OR MLH1 OR MSH2 OR MSH6 OR MUTYH OR PMS2 OR PTEN OR SMAD4 OR STK11 OR TP53)

Organ (Medline Search): colon

Medline Searches: (APC[All Fields] OR ("bone morphogenetic protein receptors, type i"[MeSH Terms] OR "type i bone morphogenetic protein receptors"[All Fields] OR "bmpr1a"[All Fields]) OR CDH1[All Fields] OR CHEK2[All Fields] OR ("tumor-associated antigen GA733"[Supplementary Concept] OR "tumor-associated antigen GA733"[All Fields] OR "epcam"[All Fields]) OR MLH1[All Fields] OR MSH2[All Fields] OR MSH6[All Fields] OR MUTYH[All Fields] OR PMS2[All Fields] OR PTEN[All Fields] OR SMAD4[All Fields] OR STK11[All Fields] OR TP53[All Fields]) AND ("colonic neoplasms"[MeSH Terms] OR ("colonic"[All Fields] AND "neoplasms"[All Fields]) OR "colonic neoplasms"[All Fields] OR ("colon" [All Fields] AND "cancer"[All Fields]) OR "colon cancer"[All Fields]) AND "humans"[MeSH Terms]

Medline hits=3646

FDA approved: No

### Gene Test Information: Coloprint®, Colon Cancer

Test Name: ColoPrint® Colon Cancer Gene Expression Test

Description: ColoPrint is an 18-gene profile that classifies colon cancer into Low Risk or High Risk of relapse, by measuring genes representative of the metastatic pathways of colon cancer metastases which were selected for their predictive relationship to 5-year distant metastases probability.

ColoPrint is indicated for stage II colon cancer, and provides relapse risk stratification independent of clinical and pathologic factors such as T4-stage and MSI status.

Purpose: Prognosis, recurrence, and therapeutic management of colon cancer

Availability: Agendia

Specimen: Fresh tumor tissue

Methodology: Genomic signature by microarray-based RNA gene expression

Diseases: Colon cancer

Clinical Uses: ColoPrint determines if the patient is a candidate for chemotherapy.

Sources: www.Agendia.com

Marker (Medline Search): Coloprint

Organ (Medline Search): Colon

Medline Searches: Coloprint[All Fields] AND ("colonic neoplasms" [MeSH Terms] OR ("colonic"[All Fields] AND "neoplasms"[All Fields]) OR "colonic neoplasms" [All Fields] OR ("colon"[All Fields] AND "cancer"[All Fields]) OR "colon cancer"[All Fields])

Medline hits=3

FDA approved: No

### Gene Test Information: ColoSeq™ - Lynch and Polyposis Syndrome Panel

Test Name: ColoSeq™ - Lynch and Polyposis Syndrome Panel

Description: ColoSeq™ is a comprehensive genetic test for hereditary colon cancer that uses next-generation sequencing to detect mutations in multiple genes associated with Lynch syndrome (hereditary non-polyposis colorectal cancer, HNPCC), familial adenomatous polyposis (FAP), MUTYH-associated polyposis (MAP), hereditary diffuse gastric cancer (HDGC), Cowden syndrome, Li-Fraumeni syndrome, Peutz-Jeghers syndrome, Muir-Torre syndrome, Turcot syndrome, and Juvenile Polyposis syndrome. The assay sequences all exons, introns, and flanking sequences of the 13 genes. Large deletions, duplications, and mosaicism are also detected by the assay and reported.

Purpose: Prediction and diagnoses of hereditary Colon Cancer

Availability: University of Washington Laboratory Medicine-Genetics Lab

Specimen: Blood

Methodology: RNA, Gene Sequencing

Diseases: Lynch syndrome (hereditary non-polyposis colorectal cancer, HNPCC), familial adenomatous polyposis (FAP), MUTYH-associated polyposis (MAP), hereditary diffuse gastric cancer (HDGC), Cowden syndrome, Li-Fraumeni syndrome, Peutz-Jeghers syndrome, Muir-Torre syndrome, Turcot syndrome, and Juvenile Polyposis syndrome

Clinical Uses: To determine if a person is at risk of colon cancer.

Sources: www.web.labmed.washington.edu

Marker: MLH1, MSH2, MSH6, PMS2, EPCAM, APC, MUTYH, CDH1, PTEN, STK11, TP53, SMAD4, and BMPR1A.

Organ: Colon, Rectum

Medline Searches: (MLH1[All Fields] OR MSH2[All Fields] OR MSH6[All Fields] OR PMS2[All Fields] OR ("tumor-associated antigen GA733"[Supplementary Concept] OR "tumor-associated antigen GA733"[All Fields] OR "epcam"[All Fields]) OR APC[All Fields] OR MUTYH[All Fields] OR CDH1[All Fields] OR PTEN[All Fields] OR STK11[All Fields] OR TP53[All Fields] OR SMAD4[All Fields] OR ("bone morphogenetic protein receptors, type i" [MeSH Terms] OR "type i bone morphogenetic protein receptors"[All Fields] OR "bmpr1a"[All Fields])) AND ("colorectal neoplasms, hereditary nonpolyposis"[MeSH Terms] OR ("colorectal"[All Fields] AND "neoplasms"[All Fields] AND "hereditary"[All Fields] AND "nonpolyposis" [All Fields]) OR "hereditary nonpolyposis colorectal neoplasms"[All Fields] OR ("lynch"[All Fields] AND "syndrome"[All Fields]) OR "lynch syndrome" [All Fields]) AND "humans"[MeSH Terms]

Medline hits=1698

FDA approved: No

### Gene Test Information: GCC (GUCY2C) Blood Test, Colorectal Cancer Staging Test

Test Name: Guanylyl Cyclase C (GUCY2C)

Description: Guanylyl Cyclase C (GCC or GUCY2C) a gene coding for a protein found in cells, lining the intestine from the duodenum to the rectum. It is involved in water transport, crypt morphology and suppression of tumorigenesis. It is not normally found in tissue in other parts of the body, and therefore, GCC detected outside of the intestine, indicates presence of colorectal cancer metastases. Early studies have indicated that the presence of GCC in the blood may be an early indicator of micrometastases that would otherwise escape detection by the current standard methods of monitoring. Earlier detection provides an opportunity for more immediate treatment or surgical intervention to potentially improve patient outcomes and survival rates.

Purpose: Diagnostic test

Availability: Diagnocure

Specimen: Whole Blood

Methodology: Reverse Transcriptase–Polymerase Chain Reaction

Diseases: Colorectal Cancer

Clinical Uses: Diagnostic test for recurrence by identification of micrometastasis in the blood

Sources: www.diagnocure.com

Marker (Medline Search): Guanylyl Cyclase C AND Blood

Organ (Medline Search): Colorectal cancer

Medline Searches: ("enterotoxin receptor"[Supplementary Concept] OR "enterotoxin receptor" [All Fields] OR "guanylyl cyclase c" [All Fields]) AND ("blood"[Subheading] OR "blood"[All Fields] OR "blood"[MeSH Terms]) AND ("colorectal neoplasms"[MeSH Terms] OR ("colorectal"[All Fields] AND "neoplasms"[All Fields]) OR "colorectal neoplasms"[All Fields] OR ("colorectal"[All Fields] AND "cancer"[All Fields]) OR "colorectal cancer"[All Fields])

Medline hits= 22

FDA approved: No

### Gene Test Information: ResponseDX: Colon®

Test Name: ResponseDX: Colon®

Description: ResponseDX: Colon® panel utilizes testing of multiple genes including KRAS mutation, BRAF mutation, ERCC1 expression, MSI, c-Met expression, EGFR expression, VEGFR2 expression, NRAS mutation, PIK3CA mutation, and Thymidylate synthetase.

Purpose: Therapeutic Management

Availability: Response Genetics

Specimen: Formalin-fixed, paraffin embedded (FFPE) biopsy specimen

Methodology: PCR-based tests

Diseases: Metastatic colorectal cancer

Clinical Uses: Predict disease prognosis and select patients who might benefit from alternative therapies and aids in selection of metastatic colorectal cancer patients that might benefit from EGFR-targeted monoclonal antibody therapies.

Sources: http://www.responsegenetics.com/products-services/responsedx-colon/

Marker (Medline Search): (KRAS OR BRAF OR ERCC1 OR MSI OR c-MET OR EGFR OR VEGFR2 OR PIK3CA OR NRAS)

Organ (Medline Search): Colon

Medline Searches: (("proto-oncogene proteins p21(ras) "[MeSH Terms] OR ("proto-oncogene"[All Fields] AND "proteins"[All Fields] AND "p21(ras)"[All Fields]) OR "proto-oncogene proteins p21(ras)"[All Fields] OR "kras"[All Fields]) OR BRAF[All Fields] OR ERCC1[All Fields] OR ("N-methylsuccinimide"[Supplementary Concept] OR "N-methylsuccinimide" [All Fields] OR "msi"[All Fields]) OR c-MET[All Fields] OR EGFR[All Fields] OR VEGFR2[All Fields] OR PIK3CA[All Fields] OR NRAS[All Fields]) AND ("colonic neoplasms"[MeSH Terms] OR ("colonic"[All Fields] AND "neoplasms"[All Fields]) OR "colonic neoplasms"[All Fields] OR ("colon"[All Fields] AND "cancers"[All Fields]) OR "colon cancers"[All Fields]) AND "humans"[MeSH Terms]

Medline hits= 1437

FDA approved: NoA-28

### Gene Test Information: Therascreen KRAS RGQ PCR, colorectal cancer

Test Name: Therascreen KRAS RGQ PCR

Description: Therascreen KRAS RGQ PCR Kit is intended to detect 7 mutations in codons 12 and 13 of the KRAS gene. The kit utilizes two technologies — ARMS and Scorpions — for detection of mutations in real-time PCR.

Purpose: Diagnosis and therapeutic management

Availability: QIAGEN

Specimen: Whole blood

Methodology: Real-time PCR.

Diseases: Colorectal cancer

Clinical Uses: The therascreen KRAS RGQ PCR kit is being developed as a companion diagnostic to aid clinicians, through detection of KRAS mutations, in the identification of patients with metastatic colorectal cancer (mCRC) who are more likely to benefit from cetuximab.

Sources: www.qiagen.com

Marker (Medline Search): therascreen kras rgq

Organ (Medline Search): colorectal

Medline Searches: therascreen[All Fields] AND ("proto-oncogene proteins p21(ras)"[MeSH Terms] OR ("proto-oncogene"[All Fields] AND "proteins"[All Fields] AND "p21(ras)"[All Fields]) OR "proto-oncogene proteins p21(ras)"[All Fields] OR "kras"[All Fields]) AND rgq[All Fields] AND ("colorectal neoplasms"[MeSH Terms] OR ("colorectal"[All Fields] AND "neoplasms"[All Fields]) OR "colorectal neoplasms"[All Fields] OR ("colorectal" [All Fields] AND "cancer"[All Fields]) OR "colorectal cancer"[All Fields])

Medline hits=1

FDA approved: yes

### Gene Test Information: PMS2, hereditary nonpolyposis colorectal cancer

Test Name: PMS2

Description: PMS2 test covers all coding nucleotides of gene Postmeiotic Segregation Increased, S. Cerevisiae, 2(PMS2), plus at least two and typically 20 flanking intronic nucleotides upstream and downstream of each coding exon, covering the conserved donor and acceptor splice sites, as well as typically 20 flanking nucleotides in the 5’ and 3’ UTR. This test can confirm a clinical diagnosis of HNPCC and allow early diagnosis in family members, guiding preventive measures.

Purpose: Diagnosis

Availability: LabCorp

Specimen: Whole blood, DNA is accepted.

Methodology: DNA sequencing

Diseases: Hereditary nonpolyposis colorectal cancer

Clinical Uses: can confirm a clinical diagnosis of HNPCC and allow early diagnosis in family members, guiding preventive measures

Sources: www.labcorp.com

Marker (Medline Search): PMS2 gene sequencing and

Organ (Medline Search): hereditary nonpolyposis colorectal cancer

Medline Searches: PMS2[All Fields] AND ("genes"[MeSH Terms] OR "genes"[All Fields] OR "gene"[All Fields]) AND sequencing[All Fields] AND ("colorectal neoplasms, hereditary nonpolyposis"[MeSH Terms] OR ("colorectal"[All Fields] AND "neoplasms"[All Fields] AND "hereditary"[All Fields] AND "nonpolyposis"[All Fields]) OR "hereditary nonpolyposis colorectal neoplasms"[All Fields] OR ("hereditary"[All Fields] AND "nonpolyposis"[All Fields] AND "colorectal"[All Fields] AND "cancer"[All Fields]) OR "hereditary nonpolyposis colorectal cancer"[All Fields])

Medline hits=28

FDA approved: No

### Gene Test Information: Previstage™ GCC, Colorectal Cancer Staging Test

Test Name: Previstage™ Guanylyl Cyclase C (GCC or GUCY2C)

Description: Guanylyl Cyclase C (GCC or GUCY2C) a gene coding for a protein found in cells, lining the intestine from the duodenum to the rectum. It is involved in water transport, crypt morphology and suppression of tumorigenesis. It is not normally found in tissue in other parts of the body, and therefore, GCC detected outside of the intestine, indicates presence of colorectal cancer metastases. GCC mRNA has shown to be highly accurate in detecting the spread and recurrence of colorectal cancer, respectively in lymph nodes and blood, thereby representing a significant improvement over traditional detection methods.

Purpose: Predictive test, Prognostic marker

Availability: Diagnocure

Specimen: lymph nodes

Methodology: Reverse Transcriptase–Polymerase Chain Reaction

Diseases: Colorectal Cancer

Clinical Uses: Predictive test for risk stratification of recurrence and prognostic marker for recurrence

Sources: www.diagnocure.com

Marker (Medline Search): Guanylyl Cyclase C

Organ (Medline Search): Colorectal cancer

Medline Searches: ("enterotoxin receptor"[Supplementary Concept] OR "enterotoxin receptor"[All Fields] OR "guanylyl cyclase c"[All Fields]) AND ("lymph nodes"[MeSH Terms] OR ("lymph"[All Fields] AND "nodes"[All Fields]) OR "lymph nodes"[All Fields] OR ("lymph"[All Fields] AND "node"[All Fields]) OR "lymph node"[All Fields]) AND ("colorectal neoplasms"[MeSH Terms] OR ("colorectal"[All Fields] AND "neoplasms"[All Fields]) OR "colorectal neoplasms"[All Fields] OR ("colorectal"[All Fields] AND "cancer"[All Fields]) OR "colorectal cancer"[All Fields])

Medline hits= 29

FDA approved: No

## GENITOURINARY

### Gene Test Information: Onco FISH, cervical

Test Name: Onco FISH cervical

Description: Among the many chromosomal changes observed in cervical cancer, the most consistent abnormality is detected in chromosome arm 3q.2 Studies have shown that at least 90% of invasive cervical cancer cases have a gain in the 3q arm.3,4 Additional research has demonstrated a correlation between the gain in the 3q26 copy number as the severity and stage of cervical disease progression.

Purpose: Predictive

Availability: Ikonisys

Specimen: Liquid cytology specimens

Methodology: Fluorescence in situ Hybridization

Diseases: cervical cancer (precancerous to malignancy cervical cancer)

Clinical Uses: Using this technology to look at the progression of individual patients, it has been shown that the sensitivity of the 3q26 loci for predicting progression from CIN1/CIN2 to CIN3 was 100% and the specificity, i.e., the prediction of regression, was 70%.

Sources: www.ikonisys.com

Marker (Medline Search): 3q26 AND Fluorescence in situ Hybridization

Organ (Medline Search): cervical

Medline Searches: 3q26[All Fields] AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence" [All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("uterine cervical neoplasms"[MeSH Terms] OR ("uterine" [All Fields] AND "cervical"[All Fields] AND "neoplasms"[All Fields]) OR "uterine cervical neoplasms" [All Fields] OR ("cervical" [All Fields] AND "cancer"[All Fields]) OR "cervical cancer"[All Fields])

Medline hits=24

FDA approved: Not Reported

### Gene Test Information: UteroFISH, Uterine

Test Name: UteroFISH

Description: UteroFISH helps distinguish between atypia or hyperplasia on an endometrial biopsy diagnosis which can have a large affect on how physicians will treat their patients. An abnormal UteroFISH result indicates a high risk (>89%) for cancer or atypical hyperplasia, and a true positive rate of 81% in patients with cancer/atypia.

Purpose: provide help on how physicians will treat their patients, therapeutic purpose

Availability: Gynecor

Specimen: biopsy

Methodology: Fluorescence in situ Hybridization

Diseases: Uterine cancer

Clinical Uses: The UteroFISH test results may aid to establish atypia or cancer. The test result infromation can save a woman from having to undergo an unnecessary hysterectomy.

Sources: www.gynector.com

Marker (Medline Search): Utero Fluorescence in situ Hybridization

Organ (Medline Search): Uterine cancer

Medline Searches: ("uterus"[MeSH Terms] OR "uterus"[All Fields] OR "utero"[All Fields]) AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization" [All Fields])) AND ("uterine neoplasms"[MeSH Terms] OR ("uterine"[All Fields] AND "neoplasms" [All Fields]) OR "uterine neoplasms"[All Fields] OR ("uterine"[All Fields] AND "cancer"[All Fields]) OR "uterine cancer"[All Fields])

Medline hits=58

FDA approved: No

### Gene Test Information: UroVysion FISH, bladder cancer

Test Name: UroVysion Fluorescence in situ hybridization (FISH) analysis

Description: The UroVysion Bladder Cancer Kit (UroVysion Kit) is designed to detect aneuploidy for chromosomes 3, 7, 17, and loss of the 9p21 locus via fluorescence in situ hybridization (FISH) in urine specimens from persons with hematuria suspected of having bladder cancer. FISH analysis is used in conjunction with cystoscopy to monitor for recurrence among those with previously diagnosed bladder cancer.

Purpose: Diagnosis and monitoring for recurrence

Availability: Abbott, Baycare Laboratories

Specimen: Urine

Methodology: Fluorescence in situ hybridization (FISH)

Diseases: Bladder cancer

Clinical Uses: FISH analysis is a surveillance tool in established primary and secondary bladder adenocarcinoma.

Sources: www.abbottmolecular.com; www.baycare.org/laboratories

Marker (Medline Search): Fluorescence in situ hybridization

Organ (Medline Search): bladder cancer

Medline Searches: ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("urinary bladder neoplasms"[MeSH Terms] OR ("urinary"[All Fields] AND "bladder"[All Fields] AND "neoplasms"[All Fields]) OR "urinary bladder neoplasms" [All Fields] OR ("bladder"[All Fields] AND "cancer"[All Fields]) OR "bladder cancer"[All Fields])

Medline hits=469

FDA approved: Yes

## HEMATOLOGICAL

### Gene Test Information: 5q del, 7q del/-7 FISH test, Acute myeloid leukemia and myelodysplastic syndrome

Test Name: 5q del, 7q del/-7 FISH test

Description: Chromosomal abnormalities are detected in 40–60% of patients with de novo myelodysplastic syndromes (MDS). MDS with interstitial deletion of a segment of the long arm of chromosome 5q [del(5q)] as an isolated cytogenetic abnormality is characterized by bone marrow erythroid hyperplasia, atypical megakaryocytes, thrombocythemia, refractory anemia, and low risk of progression to acute myeloid leukemia(AML) compared with other types of MDS. In published studies Presence of -7/7q- was associated with shorter overall survival than absence of such aberrations. FISH 7q could be beneficial in patients with intermediate WHO morphologic risk stratification and no evidence of -7/7q- by cytogenetics.

Purpose: Prognostic and therapeutic management.

Availability: Arup laboratories and other laboratories such as community, academic, and other commercial laboratories.

Specimen: Bone marrow or whole blood

Methodology: Fluorescence in-situ hybridization

Diseases: Acute myelogenous leukemia with myelodysplastic syndrome

Clinical Uses: The 5q del, 7q del/-7 FISH test may aid in prognosis of acute myeloid leukemia and myelodysplastic syndrome. It helps a subset of patients get treatment tailored to their unique genetic profile

Sources: www.ncbi.nlm.nih.gov, www.aruplab.com

Marker (Medline Search): 5q del OR -7/7q del

Organ (Medline Search): Acute myeloid leukemia AND myelodysplastic syndrome

Medline Searches: ((5q[All Fields] AND del[All Fields]) OR (7q[All Fields] AND del[All Fields])) AND (("leukemia, myeloid, acute"[MeSH Terms] OR ("leukemia"[All Fields] AND "myeloid"[All Fields] AND "acute"[All Fields]) OR "acute myeloid leukemia"[All Fields] OR ("acute"[All Fields] AND "myeloid"[All Fields] AND "leukemia"[All Fields])) AND ("myelodysplastic syndromes"[MeSH Terms] OR ("myelodysplastic"[All Fields] AND "syndromes"[All Fields]) OR "myelodysplastic syndromes"[All Fields] OR ("myelodysplastic"[All Fields] AND "syndrome"[All Fields]) OR "myelodysplastic syndrome"[All Fields]))

Medline hits=111

FDA approved: No

### Gene Test Information: 17p deletion

Test Name: 17p deletion

Description: The deletion of 17p is a bad prognosis factor for patients with Chronic Lymphocytic Leukemia. del(17p) typically involves TP53 locus and del(11q) contains ATM gene, both of which are tumor suppressors. Loss of p53 function or its activator, the ATM gene, is associated with treatment resistance and clinically aggressive disease.

Purpose: Prognosis of Chronic Lymphocytic Leukemia

Availability: Multiple Laboratories, including Arup Laboratories and Abbott Laboratories

Specimen: Blood

Methodology: Fluorescence in situ hybridization (FISH)

Diseases: Chronic lymphocytic leukemia (CLL)

Clinical Uses: Predicts poor prognosis of Chronic Lymphocytic Leukemia

Sources: www.aruplab.com, www.abbottmolecular.com

Marker: 17p deletion

Organ: Chronic Lymphocytic Leukemia

Medline Searches: (17[All Fields] AND p[All Fields] AND ("sequence deletion"[MeSH Terms] OR ("sequence"[All Fields] AND "deletion"[All Fields]) OR "sequence deletion"[All Fields] OR "deletion"[All Fields])) AND ("chronic lymphocytic leukaemia"[All Fields] OR "leukemia, lymphocytic, chronic, b-cell"[MeSH Terms] OR ("leukemia"[All Fields] AND "lymphocytic"[All Fields] AND "chronic"[All Fields] AND "b-cell"[All Fields]) OR "b-cell chronic lymphocytic leukemia"[All Fields] OR ("chronic"[All Fields] AND "lymphocytic"[All Fields] AND "leukemia"[All Fields]) OR "chronic lymphocytic leukemia"[All Fields]) AND "humans"[MeSH Terms]

Medline hits=59

FDA approved: No

### Gene Test Information: Multiple myeloma panel by FISH

Test Name: Multiple myeloma panel FISH test

Description: Chromosomal abnormalities are important prognostic indicators in multiple myeloma. In this test, fluorescence in situ hybridization (FISH) panel is performed on bone marrow or tissue containing neoplastic plasma cells for multiple myeloma prognosis-specific genomic abnormalities: for example, CKS1B (1q gain), ASS1 (+9), CCND1/IGH (IGH/CCND1 fusion or +11), IGH rearrangement, PML (+15) and p53 (17p deletion).

Purpose: Prognostic and therapeutic management.

Availability: Arup laboratories and other laboratories such as community, academic, and other commercial laboratories.

Specimen: Bone marrow or whole blood

Methodology: Fluorescence in-situ hybridization

Diseases: Multiple myeloma

Clinical Uses: The FISH test may aid in prognosis of multiple myeloma. It helps a subset of patients get treatment tailored to their unique genetic profile

Sources: www.ncbi.nlm.nih.gov, www.aruplab.com

Marker (Medline Search): CD138+ OR CD138 positive

Organ (Medline Search): Multiple myeloma

Medline Searches: ("syndecan-1"[MeSH Terms] OR "syndecan-1"[All Fields] OR "cd138"[All Fields]) AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("multiple myeloma"[MeSH Terms] OR ("multiple"[All Fields] AND "myeloma"[All Fields]) OR "multiple myeloma"[All Fields])

Medline hits=35

FDA approved: No

### Gene Test Information: MyPRS Plus

Test Name: MyPRS Plus

Description: MyPRS Plus analyzes all of the nearly 25,000 genes in a patient’s genome to determine the gene expression profile that is associated with their condition. In the case of myeloma, the gene expression profile is made up of the 70 most relevant genes which aid in the prediction of the patient’s outcome.

Purpose: Prognosis and Therapeutic management of Myeloma

Availability: Signal Genetics

Specimen: Bone Marrow Aspirate

Methodology: Gene Sequencing

Diseases: Myeloma

Clinical Uses: Helps patients and physicians determine the best treatment for patients with Myeloma.

Sources: www.signalgenetics.com, www.anthem.com/medicalpolicies/policies/mp_pw_c139353.htm

Marker (Medline Search): Not reported

Organ (Medline Search): Bone

Medline Searches: MyPRS AND Plus AND myeloma

Medline hits= No PubMed citations found.

FDA approved: No

## Lung

### Gene Test Information: ALK FISH, Lung cancer

Test Name: ALK FISH

Description: A rearrangement of anaplastic lymphoma kinase (ALK) is reported to be associated with the development of non-small-cell lung cancer (NSCLC)

Purpose: Diagnosis and therapeutic management

Availability: LabCorp

Specimen: Fixed cell pellet from a cytogenetic analysis

Methodology: Polymerase chain reaction (PCR), direct DNA sequencing, fluorescence in situ hybridization (FISH)

Diseases: Lung cancer

Clinical Uses: ALK FISH probe is used to identify gene rearrangements involving the ALK gene in patients with NSCLC who are eligible for treatment with crizotinib.

Sources: www.labcorp.com

Marker: ALK fluorescence in situ hybridization

Organ: lung

Medline Searches: ALK[All Fields] AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("lung neoplasms"[MeSH Terms] OR ("lung"[All Fields] AND "neoplasms"[All Fields]) OR "lung neoplasms"[All Fields] OR ("lung"[All Fields] AND "cancer"[All Fields]) OR "lung cancer"[All Fields])

Medline hits=65

FDA approved: Yes

### Gene Test Information: ResponseDX:Lung®

Test Name: ResponseDX:Lung®

Description: ResponseDX:Lung® panel utilizes testing of multiple genes including ROS1 rearrangements, EGFR mutation, EML4-ALK rearrangement, ALK, ERCC1 expression, RRM1 expression, c-MET expression, TS expression, KRAS mutation, and PIK3CA mutation.

Purpose: Therapeutic Management

Availability: Responsegenetics.com

Specimen: Formalin-fixed, paraffin embedded (FFPE) biopsy specimen

Methodology: Fluorescence in situ hybridization (FISH) and polymerase chain reaction (PCR)

Diseases: Non-small cell lung cancers

Clinical Uses: Patients with lung cancer who are being considered for treatment with the tyrosine kinase inhibitor (TKI) crizotinib

Sources: www.responsegenetics.com

Marker (Medline Search): ROS1 OR EGFR mutation OR EML4-ALK OR ALK OR ERCC1 OR RRM1 OR c-MET OR TS OR KRAS mutation OR PIK3CA mutation

Organ (Medline Search): Non-small cell lung cancers

Medline Searches: (ROS1[All Fields] OR EGFR[All Fields] OR EML4-ALK[All Fields] OR ALK[All Fields] OR ERCC1[All Fields] OR RRM1[All Fields] OR c-MET[All Fields] OR TS[All Fields] OR ("proto-oncogene proteins p21(ras)"[MeSH Terms] OR ("proto-oncogene"[All Fields] AND "proteins"[All Fields] AND "p21(ras)"[All Fields]) OR "proto-oncogene proteins p21(ras)"[All Fields] OR "kras"[All Fields]) OR PIK3CA[All Fields]) AND (Non-small[All Fields] AND ("cells"[MeSH Terms] OR "cells"[All Fields] OR "cell"[All Fields]) AND ("lung neoplasms"[MeSH Terms] OR ("lung"[All Fields] AND "neoplasms"[All Fields]) OR "lung neoplasms"[All Fields] OR ("lung"[All Fields] AND "cancers"[All Fields]) OR "lung cancers"[All Fields])) AND "humans"[MeSH Terms]

Medline hits= 1970

FDA approved: No

### Gene Test Information: Vysis ALK FISH test, Lung cancer

Test Name: Vysis ALK FISH test

Description: Anaplastic lymphoma kinase (ALK) encodes a receptor tyrosine kinase, and ALK gene rearrangement (ALK+) is implicated in the oncogenesis of non-small cell lung carcinomas (NSCLCs), especially adenocarcinomas. The ALK inhibitor crizotinib was approved in August 2011 by the US Food and Drug Administration (FDA) for treating late-stage NSCLCs that are ALK+, with a companion fluorescent in situ hybridization (FISH) test using the Vysis ALK Break Apart fluorescence in-situ hybridization (FISH)Probe Kit. The Abbott ALK test has been designed to identify those patients - about 3 to 5 percent of NSCLC patients - who would be candidates for the new drug.

Purpose: Therapeutic management

Availability: Abbott

Specimen: Not reported

Methodology: Fluorescence in-situ hybridization

Diseases: Non-small-cell lung cancer

Clinical Uses: The Vysis ALK FISH test uses Abbott's fluorescence in situ hybridization (FISH) technology to detect rearrangements of the ALK gene on the 2p23 chromosome. It helps a subset of lung-cancer patients get treatment tailored to their unique genetic profile

Sources: www.AbbottALK.com

Marker (Medline Search): ALK fluorescence in-situ hybridization and lung cancer

Organ (Medline Search): lung

Medline Searches: ALK[All Fields] AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND ("lung neoplasms"[MeSH Terms] OR ("lung"[All Fields] AND "neoplasms"[All Fields]) OR "lung neoplasms"[All Fields] OR ("lung"[All Fields] AND "cancer"[All Fields]) OR "lung cancer"[All Fields])

Medline hits=64

FDA approved: Yes

### Gene Test Information: PreOvar

Test Name: PreOvar

Description: PreOvar™ tests for the KRAS-variant, and will help identify ovarian cancer patients whose female relatives should also be evaluated for the KRAS-variant. PreOvar™ may also help assess the relative risk of developing ovarian cancer for women who have a family history of ovarian cancer without a living proband (ancestor with the disease). The KRAS-Variant is present in 6–10% of the general population and 25% of non-selected women with epithelial ovarian cancer. Additionally, the KRAS-variant was identified in over 60% of Hereditary Breast and Ovarian Cancer (HBOC) patients that were previously classified as “uninformative,” or negative for other known genetic markers of ovarian cancer risk.

Purpose: Prediction of the risk of developing ovarian cancer.

Availability: Mira DX

Specimen: Blood, Saliva

Methodology: RNA

Diseases: Ovarian Cancer

Clinical Uses: Test determines if KRAS-variant may put someone at increased risk for developing ovarian cancer.

Sources: www.miradx.com/preovar

Marker: KRAS-variant

Organ: Ovaries

Medline Searches: (("proto-oncogene proteins p21(ras)"[MeSH Terms] OR ("proto-oncogene"[All Fields] AND "proteins"[All Fields] AND "p21(ras)"[All Fields]) OR "proto-oncogene proteins p21(ras)"[All Fields] OR "kras"[All Fields]) AND variant[All Fields]) AND ("ovarian neoplasms"[MeSH Terms] OR ("ovarian"[All Fields] AND "neoplasms"[All Fields]) OR "ovarian neoplasms"[All Fields] OR ("ovarian"[All Fields] AND "cancer"[All Fields]) OR "ovarian cancer"[All Fields]) AND "humans"[MeSH Terms]

Medline hits=9

FDA approved: No

## PROSTATE

### Gene Test Information: Adenomatous polyposis coli (APC), Prostate cancer

Test Name: Adenomatous polyposis coli (APC)

Description: Prostate cancer is the most common cancer in men and the second leading cause of cancer-related deaths in the US. Due to the reportedly high false-negative rate of initial biopsy results after elevated PSA level, new approaches for improved detection in prostate cancer are needed. Several studies have shown that hypermethylation of the promoter regions of the GST-P1 and APC genes occurs at a significantly higher frequency in prostate cancer samples than in benign conditions of the prostate gland.

Purpose: Prognostic

Availability: Labcorp

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue

Methodology: Quantitative methylation-specific polymerase chain reaction (PCR)

Diseases: Prostate cancer

Clinical Uses: Gene methylation assays of Adenomatous polyposis coli (APC) may be used as an adjunct to histopathology for patients where prostate disease is considered.

Sources: www.labcorp.com

Marker (Medline Search): adenomatous polyposis coli and polymerase chain reaction

Organ (Medline Search): prostate

Medline Searches: ("adenomatous polyposis coli"[MeSH Terms] OR ("adenomatous"[All Fields] AND "polyposis"[All Fields] AND "coli"[All Fields]) OR "adenomatous polyposis coli"[All Fields]) AND ("polymerase chain reaction"[MeSH Terms] OR ("polymerase"[All Fields] AND "chain"[All Fields] AND "reaction"[All Fields]) OR "polymerase chain reaction"[All Fields]) AND ("prostatic neoplasms"[MeSH Terms] OR ("prostatic"[All Fields] AND "neoplasms"[All Fields]) OR "prostatic neoplasms"[All Fields] OR ("prostate"[All Fields] AND "cancer"[All Fields]) OR "prostate cancer"[All Fields])

Medline hits=14

FDA approved: No

### Gene Test Information: Glutathione-S-Transferase (GST-P1), Prostate cancer

Test Name: Glutathione-S-Transferase (GST-P1)

Description: Prostate cancer is the most common cancer in men and the second leading cause of cancer-related deaths in the US. Due to the reportedly high false-negative rate of initial biopsy results after elevated PSA level, new approaches for improved detection in prostate cancer are needed. Several studies have shown that hypermethylation of the promoter regions of the GST-P1 and APC genes occurs at a significantly higher frequency in prostate cancer samples than in benign conditions of the prostate gland.

Purpose: Prognostic

Availability: Labcorp

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue

Methodology: Quantitative methylation-specific polymerase chain reaction (PCR)

Diseases: Prostate cancer

Clinical Uses: Hypermethylation of the promoter regions of the GST-P1 and APC genes can aid in prognosticating for prostate cancer

Sources: www.labcorp.com

Marker (Medline Search): Glutathione-S-Transferase and polymerase chain reaction

Organ (Medline Search): Prostate

Medline Searches: ("glutathione transferase"[MeSH Terms] OR ("glutathione"[All Fields] AND "transferase"[All Fields]) OR "glutathione transferase"[All Fields] OR "glutathione s transferase"[All Fields]) AND ("polymerase chain reaction"[MeSH Terms] OR ("polymerase"[All Fields] AND "chain"[All Fields] AND "reaction"[All Fields]) OR "polymerase chain reaction"[All Fields]) AND ("prostatic neoplasms"[MeSH Terms] OR ("prostatic"[All Fields] AND "neoplasms"[All Fields]) OR "prostatic neoplasms"[All Fields] OR ("prostate"[All Fields] AND "cancer"[All Fields]) OR "prostate cancer"[All Fields])

Medline hits=118

FDA approved: No

### Gene Test Information: Oncotype DX Prostate

Test Name: Oncotype DX Prostate

Description: The Oncotype DX test for prostate cancer is a genomic test that determines the risk of the cancer before treatment begins. The test predicts how likely it is that the cancer is low risk and contained within the prostate, or higher risk and more likely to grow and spread. With this information, the patient and their doctor can choose the most appropriate treatment option. For example, a lower risk prostate cancer with more favorable pathology, one that may not need invasive treatment and can be safely managed through close and careful monitoring – a treatment approach called active surveillance.

This genomic test measures biology through the expression of 17 genes across multiple key biological pathways in prostate cancer which can predict the aggressiveness of prostate cancer providing a individualized risk assessment.

Purpose: Therapeutic management of early-stage prostate cancer

Availability: Genomic Health, Inc.

Specimen: Tissue

Methodology: Immunohistochemistry

Diseases: Prostate Cancer

Clinical Uses: The results of this test are combined with PSA level and Gleason Score to determine the best treatment (Active Surveillance or Immediate Treatment) for patients with early-stage prostate cancer.

Sources: www.genomichealth.com/OncotypeDX

Marker: FAM13C, KLK2, AZGP1, SRD5A2, BGN, COL1A1, SFRP4, ARF, ATP5E, CLTC, GPS1, PGK1, FLNC, GSN, TPM2, GSTM2, TPX2

Organ: Prostate

Medline Searches: 4-dehydrogenase"[All Fields] OR "srd5a2"[All Fields]) OR BGN[All Fields] OR COL1A1[All Fields] OR SFRP4[All Fields] OR ARF[All Fields] OR ATP5E[All Fields] OR CLTC[All Fields] OR GPS1[All Fields] OR PGK1[All Fields] OR FLNC[All Fields] OR GSN[All Fields] OR TPM2[All Fields] OR GSTM2[All Fields] OR TPX2[All Fields]) AND ("prostatic neoplasms"[MeSH Terms] OR ("prostatic"[All Fields] AND "neoplasms"[All Fields]) OR "prostatic neoplasms"[All Fields] OR ("prostate"[All Fields] AND "cancer"[All Fields]) OR "prostate cancer"[All Fields]) AND "humans"[MeSH Terms]

Medline hits=402

FDA approved: No

### Gene Test Information: ProstaVysion, Prostate Cancer

Test Name: ProstaVysion

Description: ProstaVysion is a prognostic genetic panel for prostate cancer. This test examines two major mechanisms of prostate carcinogenesis: ERG gene fusion/translocation and the loss of the PTEN tumor suppressor gene. This test is a tissue-based panel. By examining these two markers, ProstaVysion is able to provide a molecular analysis of prostate cancer aggressiveness and long-term patient prognosis. ERG gene fusions are found in 40% of primary prostate cancers and are associated with a more aggressive phenotype. Deletion of PTEN occurs in both localized prostate cancers and 60% of metastases.

Purpose: Prognosis and therapeutic management

Availability: Bostwick Labs

Specimen: Not reported

Methodology: Not reported

Diseases: Prostate cancer

Clinical Uses: ProstaVysion panel markers provide prognostic information and aid in therapeutic choices

Sources: www.bostwicklaboratories.com

Marker: ERG AND PTEN loss

Organ: Prostate cancer

Medline Searches: erg[All Fields] AND pten[All Fields] AND loss[All Fields] AND ("prostatic neoplasms"[MeSH Terms] OR ("prostatic"[All Fields] AND "neoplasms"[All Fields]) OR "prostatic neoplasms"[All Fields] OR ("prostate"[All Fields] AND "cancer"[All Fields]) OR "prostate cancer"[All Fields])

Medline hits=19

FDA approved: Not reported

## Other

### Gene Test Information: Cobas® BRAF V600 mutation, Melanoma

Test Name: Cobas® BRAF V600 Mutation

Description: Somatic mutations in the BRAF oncogene are frequently found in human cancers. These mutations are common in melanomas, colorectal cancer, lung cancer, ovarian cancer, and thyroid gland cancer.

Purpose: Therapeutic management

Availability: Roche diagnostics

Specimen: Formalin-fixed, paraffin-embedded (FFPE) melanoma tissue from humans.

Methodology: Polymerase chain reaction (PCR)

Diseases: Melanoma.

Clinical Uses: It is designed to help select patients for treatment with vemurafenib, an oral medicine designed to treat patients whose melanoma tumors that harbor a mutated form of the BRAF gene.

Sources: www.molecular.roche.com

Marker (Medline Search): BRAF gene mutation detection

Organ (Medline Search): Melanoma

Medline Searches: (BRAF[All Fields] AND v600[All Fields] AND ("mutation"[MeSH Terms] OR "mutation"[All Fields]) AND ("melanoma"[MeSH Terms] OR "melanoma"[All Fields])) AND ("PLX4032"[Supplementary Concept] OR "PLX4032"[All Fields] OR "vemurafenib"[All Fields])

Medline hits=32

FDA approved: No

### Gene Test Information: BRAF gene mutation detection, Multiple

Test Name: BRAF gene mutation detection

Description: Somatic mutations in the BRAF oncogene are frequently found in human cancers. These mutations are common in melanomas, colorectal cancer, lung cancer, ovarian cancer, and thyroid gland cancer.

Purpose: Therapeutic management

Availability: Labcorp and other laboratories

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue.

Methodology: Amplification refractory mutation system (ARMS) and real-time polymerase chain reaction (PCR) using Scorpions technology.

Diseases: Multiple cancers (melanomas, colorectal cancer, lung cancer, ovarian cancer and thyroid gland cancer).

Clinical Uses: More than 90% of mutations are the V600E (1799T>A) mutation. Recent studies have shown that metastatic colorectal cancer patients with this BRAF mutation do not have a strong response to anti-EGFR therapies such as cetuximab and panitumumab. This assay detects any amino acid change that has an A nucleotide at position 1799 in exon 15 of the BRAF gene regardless of any other common changes (could detect V600E/V600K/V600D), allowing identification of patients who are likely to benefit from such treatment.

Sources: www.labcorp.com

Marker (Medline Search): BRAF gene mutation detection

Organ (Medline Search): Melanoma

Medline Searches: BRAF[All Fields] AND ("genes"[MeSH Terms] OR "genes"[All Fields] OR "gene"[All Fields]) AND ("mutation"[MeSH Terms] OR "mutation"[All Fields]) AND detection[All Fields] AND ("melanoma"[MeSH Terms] OR "melanoma"[All Fields])

Medline hits=19

FDA approved: No

### Gene Test Information: NeoSITE Melanoma

Test Name: NeoSITE Melanoma

Description: NeoSITE Melanoma is a second-generation FISH assay that aids diagnostic discrimination between nevi and melanoma by informing of chromosomal gains or losses in four regions predictive of malignancy. This modified version improves classification of morphologically borderline lesions and detection of spitzoid melanoma, to control for tetraploidy, and to include 8q24 and 9p21 markers.

Purpose: Diagnostic of melanoma.

Availability: NeoGenomics

Specimen: Paraffin Block, Cut Slides

Methodology: Fluorescence in situ hybridization (FISH)

Diseases: Melanoma

Clinical Uses: To aid in the discrimination between nevi and melanoma.

Sources: www.neogenomics.com/neosite-melanoma.htm

Marker (Medline Search): RREB1 OR 6p25; MYC OR 8q24 OR p16(CDKN2A) OR 9p21 OR CCND1 OR 11Q13 OR Cen 9 OR Centromere

Organ (Medline Search): Melanoma

Medline Searches: (RREB1[All Fields] OR (6p25;[All Fields] AND MYC[All Fields]) OR 8q24[All Fields] OR p16[All Fields] AND ("genes, p16"[MeSH Terms] OR ("genes"[All Fields] AND "p16"[All Fields]) OR "p16 genes"[All Fields] OR "cdkn2a"[All Fields] OR "cyclin-dependent kinase inhibitor p16"[MeSH Terms] OR ("cyclin-dependent"[All Fields] AND "kinase"[All Fields] AND "inhibitor"[All Fields] AND "p16"[All Fields]) OR "cyclin-dependent kinase inhibitor p16"[All Fields]) OR 9p21[All Fields] OR ("cyclin d1"[MeSH Terms] OR ("cyclin"[All Fields] AND "d1"[All Fields]) OR "cyclin d1"[All Fields] OR "ccnd1"[All Fields]) OR 11Q13[All Fields] OR (Cen[All Fields] AND 9[All Fields]) OR ("centromere"[MeSH Terms] OR "centromere"[All Fields])) AND ("melanoma"[MeSH Terms] OR "melanoma"[All Fields]) AND "humans"[MeSH Terms]

Medline hits=1076

FDA approved: No

### Gene Test Information: MEN2 (RET) DNA sequencing test, pheochromocytoma

Test Name: MEN2 rearranged during transfection (RET) DNA sequencing test

Description: MEN type 2 (MEN2) conditions represent at least four different syndromes that associate pheochromocytomawith medullary thyroid carcinoma, hyperparathyroidism, and a number of other manifestations. MEN2 rearranged during transfection (RET) DNA sequencing test detects mutations in the coding sequences of the RET genes for diagnosis.

Purpose: Diagnosis.

Availability: Athena diagnostics

Specimen: Whole blood

Methodology: Polymerase chain reaction (PCR) and DNA sequencing

Diseases: Pheochromocytoma

Clinical Uses: MEN2 rearranged during transfection (RET) DNA sequencing test detects mutations in the coding sequences of the RET genes and may aid clinical diagnoses of pheochromocytoma and associated clinical manifestations

Sources: www.athenadiagnostics.com

Marker: MEN2

Organ: thyroid

Medline Searches: MEN2[All Fields] AND ("phaeochromocytoma"[All Fields] OR "pheochromocytoma"[MeSH Terms] OR "pheochromocytoma"[All Fields])

Medline hits=84

FDA approved: No

### Gene Test Information: miRInform™ Pancreas

Test Name: miRInform™ Pancreas

Description: miRInform™ Pancreas is a molecular diagnostic test, performed on fine needle aspirate (FNA) biopsies of solid lesions, that aids in the pre-operative diagnosis and disease management of pancreatic ductal adenocarcinoma (PDAC) patients.

Purpose: Aids in the pre-operative diagnosis and disease management of pancreatic ductal adenocarcinoma (PDAC) patients

Availability: Asuragen, Inc

Specimen: Fine needle aspirate (FNA) biopsies of solid lesions

Methodology: Reverse transcription quantitative polymerase chain reaction (RT-qPCR) analysis

Diseases: Pancreatic Cancer

Clinical Uses: Helps physicians diagnose indeterminate, atypical and suspicious cytopathology result and plan for best treatment.

Sources: www.asuragen.com

Marker: miRNA

Organ: Pancreas

Medline Searches: (("micrornas"[MeSH Terms] OR "micrornas"[All Fields] OR "mirna"[All Fields]) AND ("pancreatic neoplasms"[MeSH Terms] OR ("pancreatic"[All Fields] AND "neoplasms"[All Fields]) OR "pancreatic neoplasms"[All Fields] OR ("pancreatic"[All Fields] AND "cancer"[All Fields]) OR "pancreatic cancer"[All Fields])) AND "humans"[MeSH Terms]

Medline hits=237

FDA approved: No

### Gene Test Information: PIK3CA Oncogene mutation detection, Liver

Test Name: PIK3CA Oncogene mutation detection

Description: Somatic mutations in the PIK3CA oncogene are frequently found in human cancers. They are common in liver cancer, breast cancer, colorectal cancer, and ovarian cancer. These mutations may indicate prognosis and drug response. This assay detects four PIK3CA mutations (H1047R, E542K, E545D, E545K) in exon 9 and 20, allowing determination of whether there is a correlation between PIK3CA mutation status and drug response to PIK3 inhibitors like EGFR-targeted MoAbs.

Purpose: Prognosis and therapeutic management

Availability: LabCorp

Specimen: Formalin-fixed, paraffin-embedded (FFPE) tissue

Methodology: Amplification refractory mutation system (ARMS) and realtime polymerase chain reaction (PCR) using Scorpions technology.

Diseases: Multiple cancers (liver cancer, breast cancer, colorectal cancer, and ovarian cancer)

Clinical Uses: PIK3CA mutation status may aid to assess drug response like EGFR-targeted MoAbs.

Sources: www.labcorp.com

Marker: PIK3CA Oncogene mutation detection

Organ: Liver cancer

Medline Searches: PIK3CA[All Fields] AND ("oncogenes"[MeSH Terms] OR "oncogenes"[All Fields] OR "oncogene"[All Fields]) AND ("mutation"[MeSH Terms] OR "mutation"[All Fields]) AND detection[All Fields] AND ("neoplasms"[MeSH Terms] OR "neoplasms"[All Fields] OR "cancer"[All Fields])

Medline hits=25

FDA approved: No

### Gene Test Information: PDGFRA mutation analysis, Gastrointestinal stromal tumors

Test Name: PDGFRA mutation analysis

Description: Gastrointestinal stromal tumors (GISTs) are the most common mesenchymal tumor of the gastrointestinal tract, located mostly in the stomach (60%) and small instestine (35%). Approximately 80% of GISTs have a mutation in c-KIT and 5% to 10% of GISTs have a mutation on PDGFRA. Most known mutations in the PDGFRA gene are associated with imatinib response with the exception of D842V mutation. In a subset of intestinal high risk GISTs lacking c-KIT/PDGFRA mutations, 7% have a mutation in BRAF. Kinase inhibitors targeting BRAF may be effective therapeutic options in this molecular GIST subset for therapeutic management.

Purpose: Predictive and therapeutic management

Availability: LabCorp

Specimen: Formalin-fixed, paraffin-embedded tissue

Methodology: Polymerase chain reaction (PCR) and DNA sequencing

Diseases: Gastrointestinal stromal tumors

Clinical Uses: In a subset of intestinal high risk GISTs lacking c-KIT/PDGFRA mutations, 7% have a mutation in BRAF. Kinase inhibitors targeting BRAF may be effective therapeutic options in this molecular GIST subset for therapeutic management.

Sources: www.labcorp.com

Marker (Medline Search): PDGFRA mutation analysis

Organ (Medline Search): Gastrointestinal stromal tumors

Medline Searches: ("receptor, platelet-derived growth factor alpha"[MeSH Terms] OR ("receptor"[All Fields] AND "platelet-derived"[All Fields] AND "growth"[All Fields] AND "factor"[All Fields] AND "alpha"[All Fields]) OR "platelet-derived growth factor alpha receptor"[All Fields] OR "pdgfra"[All Fields]) AND ("mutation"[MeSH Terms] OR "mutation"[All Fields]) AND ("analysis"[Subheading] OR "analysis"[All Fields]) AND ("gastrointestinal stromal tumors"[MeSH Terms] OR ("gastrointestinal"[All Fields] AND "stromal"[All Fields] AND "tumors"[All Fields]) OR "gastrointestinal stromal tumors"[All Fields])

Medline hits=212

FDA approved: No

### Gene Test Information: ResponseDX:Melanoma®

Test Name: ResponseDX:Melanoma®

Description: ResponseDX:Melanoma® panel utilizes testing of multiple genes including BRAF mutation, and NRAS mutation.

Purpose: Prognosis, Therapeutic Management

Availability: Responsegenetics.com

Specimen: Formalin-fixed, paraffin embedded (FFPE) biopsy specimen

Methodology: Fluorescence in situ hybridization (FISH) and polymerase chain reaction (PCR)

Diseases: Melanoma

Clinical Uses: Patients with melanoma who are being considered for treatment with the tyrosine kinase inhibitor (TKI) and EGFR antagonists cetuximab and panitumumab.

Sources: www.responsegenetics.com

Marker (Medline Search): BRAF OR NRAS

Organ (Medline Search): Melanoma

Medline Searches: (BRAF[All Fields] OR NRAS[All Fields]) AND ("melanoma"[MeSH Terms] OR "melanoma"[All Fields])

Medline hits = 1226

FDA approved: No

### Gene Test Information: ResponseDx: Gastric®

Test Name: ResponseDX: Gastric®

Description: ResponseDX: Gastric® panel utilizes testing of multiple genes including HER2 gene amplification, ERCC1 expression, and Thymidilate Synthetase expression.

Purpose: Prognostic, therapeutic management

Availability: Response Genetics

Specimen: Formalin-fixed, paraffin embedded (FFPE) biopsy specimen

Methodology: PCR-based tests

Diseases: Advanced gastric cancers

Clinical Uses: Amplification of the HER2 gene is associated with increased disease recurrence and a worse prognosis. ERCC1 expression predicts the best therapeutic combination of agents including platinum and select patients who might benefit from platinum-based therapies. Thymidylate synthetase (TS) expression predicts the best therapeutic combination of agents including pemetrexed or 5-FU and select patients who might benefit from pemetrexed-based therapies.

Sources: www.responsegenetics.com

Marker (Medline Search): (HER2 OR ERCC1 OR Thymidylate synthetase)

Organ (Medline Search): Gastric cancer

Medline Searches: (HER2[All Fields] OR ERCC1[All Fields] OR ("thymidylate synthase"[MeSH Terms] OR ("thymidylate"[All Fields] AND "synthase"[All Fields]) OR "thymidylate synthase"[All Fields] OR ("thymidylate"[All Fields] AND "synthetase"[All Fields]) OR "thymidylate synthetase"[All Fields])) AND ("stomach neoplasms"[MeSH Terms] OR ("stomach"[All Fields] AND "neoplasms"[All Fields]) OR "stomach neoplasms"[All Fields] OR ("gastric"[All Fields] AND "cancer"[All Fields]) OR "gastric cancer"[All Fields])

Medline hits = 677

FDA approved: No

### Gene Test Information: RET gene sequencing, thyroid carcinoma

Test Name: RET gene sequencing, thyroid carcinoma

Description: this test can be used to identify genetic variations in the RET gene that are causative for MEN2. Germline mutations in the RET gene on chromosome 10 are causative for multiple endocrine neoplasia, type 2 (MEN2), a monogenic, autosomal-dominant hereditary cancer syndrome. The vast majority (>95%) of MEN2 cases have RET gene mutations in exons 10, 11, 13, 14, 15, or 16. MEN2 is characterized by the development of medullary thyroid carcinoma (MTC) and sometimes includes pheochromocytoma (PHEO) and hyperparathyroidism (HPT).

Purpose: Diagnosis

Availability: Labcorp

Specimen: whole blood

Methodology: Polymerase chain reaction (PCR) of targeted RET gene exons, DNA sequencing of those PCR products.

Diseases: Thyroid carcinoma, pheochromocytoma, and hyperparathyroidism

Clinical Uses: This test is performed on an affected individual (proband) in the suspected or defined MEN2 family. If a RET gene mutation is identified in the proband, testing for the specific family mutation may be offered to appropriate unaffected, at-risk relatives.

Sources: www.labcorp.com

Marker (Medline Search): RET gene mutation

Organ (Medline Search): thyroid cancer OR parathyroid cancer OR pheochromocytoma

Medline Searches: "ret"[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields] OR "gene"[All Fields]) AND ("mutation"[MeSH Terms] OR "mutation"[All Fields])) AND (("thyroid neoplasms"[MeSH Terms] OR ("thyroid"[All Fields] AND "neoplasms"[All Fields]) OR "thyroid neoplasms"[All Fields] OR ("thyroid"[All Fields] AND "cancer"[All Fields]) OR "thyroid cancer"[All Fields]) OR ("parathyroid neoplasms"[MeSH Terms] OR ("parathyroid"[All Fields] AND "neoplasms"[All Fields]) OR "parathyroid neoplasms"[All Fields] OR ("parathyroid"[All Fields] AND "cancer"[All Fields]) OR "parathyroid cancer"[All Fields]) OR ("phaeochromocytoma"[All Fields] OR "pheochromocytoma"[MeSH Terms] OR "pheochromocytoma"[All Fields]))

Medline hits=135

FDA approved: No

### Gene Test Information: SDHB DNA sequencing test, pheochromocytoma

Test Name: SDHB DNA sequencing test

Description: MEN type 2 (MEN2) conditions represent at least four different syndromes that associate pheochromocytoma with medullary thyroid carcinoma, hyperparathyroidism, and a number of other manifestations. It detects mutations in the coding sequences of the succinate dehydrogenase complex, subunit B (SDHB) genes. Recent investigations have found mutations in succinate dehydrogenase subunit B (SDHB), the gene coding for subunit B of the respiratory chain complex II. Mutations in the SDHB gene, with additional loss of the wild-type allele, result in loss of function of respiratory complex II and appear to correlate with extra-adrenal location of pheochromocytomas. Also, a link has been established between malignant behaviour and inactivating mutations of SDHB.

Purpose: Prognostic

Availability: Athena diagnostics

Specimen: Whole blood

Methodology: Polymerase chain reaction (PCR) and DNA sequencing

Diseases: Pheochromocytoma

Clinical Uses: SDHB DNA sequencing test detects mutations in the coding sequences of SDHB genes and may aid in prognosticating malignant behaviour of pheochromocytoma.

Sources: www.athenadiagnostics.com

Marker (Medline Search): SDHB gene

Organ (Medline Search): Pheochromocytoma

Medline Searches: SDHB[All Fields] AND ("phaeochromocytoma"[All Fields] OR "pheochromocytoma"[MeSH Terms] OR "pheochromocytoma"[All Fields])

Medline hits=234

FDA approved: No

### Gene Test Information: 1P, 19Q FISH, Oligoglioma

Test Name: 1P, 19Q FISH

Description: The oligodendroglioma (OG) type of glial cell tumors accounts for 2–5% of primary brain neoplasms and 4–15% of gliomas diagnosed worldwide. Allelic losses on 1p, or on 1p and 19q, correlate with chemotherapy response and good prognosis in OG patients

Purpose: Diagnostic and Prognostic

Availability: Labcorp

Specimen: Fixed-cell pellet from a cytogenetic analysis

Methodology: Fluorescence in situ hybridization (FISH)

Diseases: Oligoglioma

Clinical Uses: Confirmation/identification of brain cancer-related alterations and response to chemotherapy

Sources: www.labcorp.com

Marker: 1p 19q AND fluorescence in situ hybridization

Organ: Oligodendroglioma

Medline Searches: ("oligodendroglioma"[MeSH Terms] OR "oligodendroglioma"[All Fields]) AND 1p[All Fields] AND 19q[All Fields] AND ("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields]))

Medline hits=85

FDA approved: No

## MULTIPLE

### Gene Test Information: BROCA - Cancer Risk Panel

Test Name: BROCA - Cancer Risk Panel

Description: BROCA is useful for the evaluation of patients with a suspected hereditary cancer predisposition, with a focus on syndromes that include breast or ovarian cancer as one of the cancer types. Depending on the causative gene involved, these cancers may co-occur with other cancer types (such as colorectal, endometrial, pancreatic, endocrine, or melanoma). If mutations in BRCA1 or BRCA2 are suspected, these should be evaluated with a separate test.

Purpose: Prediction of the risk of breast and/ or ovarian cancer, as well as other cancers.

Availability: University of Washington Laboratory Medicine- Genetics Lab

Specimen: Blood

Methodology: RNA, Gene Sequencing

Diseases: Multiple Cancers, including breast and ovarian cancer

Clinical Uses: To determine if patient is at increase risk of developing cancer (specifically breast or ovarian cancer) and to develop a medical management plan to reduce the risk of cancer.

Sources: www.web.labmed.washington.edu

Marker: APC, ATM, ATR, BAP1, BARD1, BMPR1A, BRIP1, CDH1, CDK4, CDKN2A,CHEK1, CHEK2, FAM175A (Abraxas),GALNT12, GEN1, GREM1, HOXB13, MLH1, MRE11A, MSH2 (+EPCAM), MSH6, MUTYH, NBN, PALB2, PMS2, PRSS1, PTEN, RAD50, RAD51, RAD51C, RAD51D, RET, SMAD4, STK11, TP53,TP53BP1, VHL, and XRCC2

Organ: Multiple Organs, including Breast, Ovarian

Medline Searches: (APC[All Fields] OR ("atm"[All Fields]) OR ATR[All Fields] OR BAP1[All Fields] OR BARD1[All Fields] OR ("bone morphogenetic protein receptors, type i"[MeSH Terms] OR "type i bone morphogenetic protein receptors"[All Fields] OR "bmpr1a"[All Fields]) OR BRIP1[All Fields] OR CDH1[All Fields] OR CDK4[All Fields] OR ("genes, p16"[MeSH Terms] OR ("genes"[All Fields] AND "p16"[All Fields]) OR "p16 genes"[All Fields] OR "cdkn2a"[All Fields] OR "cyclin-dependent kinase inhibitor p16"[MeSH Terms] OR ("cyclin-dependent"[All Fields] AND "kinase"[All Fields] AND "inhibitor"[All Fields] AND "p16"[All Fields]) OR "cyclin-dependent kinase inhibitor p16"[All Fields]) OR CHEK2[All Fields] OR FAM175A[All Fields] OR GALNT12[All Fields] OR GEN1[All Fields] OR GREM1[All Fields] OR HOXB13[All Fields] OR MLH1[All Fields] OR MRE11A[All Fields] OR MSH2[All Fields] OR MSH6[All Fields] OR muty[All Fields] OR NBN[All Fields] OR PALB2[All Fields] OR PMS2[All Fields] OR PRSS1[All Fields] OR pten[All Fields] OR RAD50[All Fields] OR RAD51[All Fields] OR RAD51C[All Fields] OR RAD51D[All Fields] OR "ret"[All Fields]) OR SMAD4[All Fields] OR STK11[All Fields] OR TP53[All Fields] OR VHL[All Fields] OR XRCC2[All Fields]) AND ("neoplasms"[MeSH Terms] OR "neoplasms"[All Fields] OR "cancer"[All Fields]) AND ((Clinical Trial[ptyp] OR Comparative Study[ptyp]) AND "humans"[MeSH Terms])

Medline hits= 3041

FDA approved: No

### Gene Test Information: CancerNext™

Test Name: CancerNext™

Description: CancerNext™utilizes next generation sequencing to offer a comprehensive testing panel for hereditary colon cancer and targets detection of mutations in 22 genes (APC, BMPR1A, CDH1, CHEK2, EPCAM, MLH1, MSH2, MSH6, MUTYH, PMS2, PTEN, SMAD4, STK11, and TP53). Gross deletion/duplication analysis is performed for all 22 genes.

Purpose: Predictive

Availability: Ambry genetics

Specimen: Blood, DNA, or Saliva

Methodology: gene sequencing, deletion/duplication analysis

Diseases: Breast, Colon, Uterine, Ovarian, Other

Clinical Uses: CancerNext™ is a next-generation cancer panel that simultaneously analyzes selected genes associated with a wide range of cancers. While mutations in each gene on this panel may be individually rare, they may collectively account for a significant amount of hereditary cancer susceptibility.

Sources: www.ambrygen.com

Marker (Medline Search): (APC, ATM, BARD1, BRIP1, BMPR1A, CDH1, CHEK2, EPCAM, MLH1, MRE11A, MSH2, MSH6, MUTYH, NBN, PALB2, PMS2, PTEN, RAD50, RAD51C, SMAD4, STK11, and TP53)

Organ (Medline Search): breast OR ovarian cancer OR uterine OR colon

Medline Searches: (APC[All Fields] OR "atm"[All Fields]) OR BARD1[All Fields] OR BRIP1[All Fields] OR ("bone morphogenetic protein receptors, type i"[MeSH Terms] OR "type i bone morphogenetic protein receptors"[All Fields] OR "bmpr1a"[All Fields]) OR CDH1[All Fields] OR CHEK2[All Fields] OR ("tumor-associated antigen GA733"[Supplementary Concept] OR "tumor-associated antigen GA733"[All Fields] OR "epcam"[All Fields]) OR MLH1[All Fields] OR MRE11A[All Fields] OR MSH2[All Fields] OR MSH6[All Fields] OR MUTYH[All Fields] OR NBN[All Fields] OR PALB2[All Fields] OR PMS2[All Fields] OR PTEN[All Fields] OR RAD50[All Fields] OR RAD51C[All Fields] OR SMAD4[All Fields] OR STK11[All Fields] OR TP53[All Fields]) AND (("colon"[MeSH Terms] OR "colon"[All Fields]) OR ("breast"[MeSH Terms] OR "breast"[All Fields]) OR ("uterus"[MeSH Terms] OR "uterus"[All Fields] OR "uterine"[All Fields]) OR ("ovary"[MeSH Terms] OR "ovary"[All Fields])) AND "humans"[MeSH Terms]

Medline hits=6434

FDA approved: No

### Gene Test Information: EGFR FISH, Multiple (Lung and brain cancer)

Test Name: EGFR FISH

Description: High EGFR copy number or ratio of EGFR: control >2.0 detected by FISH has been shown to correlate with response, progression-free survival, and overall survival after treatment with EGFR TKIs in patients with non-small-cell lung cancer (NSCLC)

Purpose: Prognostic

Availability: LabCorp, Bioscience Healthcare

Specimen: Fixed cell pellet from a cytogenetic analysis

Methodology: Fluorescence in situ hybridization (FISH)

Diseases: Multiple (lung cancer and brain cancer)

Clinical Uses: High EGFR copy number or ratio of EGFR: control >2.0 detected by FISH has been shown to correlate with response, progression-free survival, and overall survival after treatment with EGFR TKIs in patients with non-small-cell lung cancer (NSCLC). It is used for prognostic of lung and brain cancer.

Sources: www.labcorp.com

Marker (Medline Search): EGFR fluorescence in situ hybridization

Organ (Medline Search): lung and brain cancer

Medline Searches: (("in situ hybridization, fluorescence"[MeSH Terms] OR ("situ"[All Fields] AND "hybridization"[All Fields] AND "fluorescence"[All Fields]) OR "fluorescence in situ hybridization"[All Fields] OR ("fluorescence"[All Fields] AND "situ"[All Fields] AND "hybridization"[All Fields])) AND EGFR[All Fields]) AND (("lung"[MeSH Terms] OR "lung"[All Fields]) OR ("brain"[MeSH Terms] OR "brain"[All Fields]))

Medline hits=334

FDA approved: No

### Gene Test Information: OVANEXT

Test Name: OVANEXT

Description: OvaNextTM is a next generation (next-gen) sequencing panel that simultaneously analyses 19 genes that contribute to increased risk for breast, ovarian, and/or uterine cancers

Purpose: Prediction of risk of breast, ovarian, or uterine cancer.

Availability: Ambry Genetics

Specimen: Blood, DNA, Saliva

Methodology: Next Generation Gene Sequencing

Diseases: Breast, Ovarian, and/or Uterine Cancer

Clinical Uses: To determine if a woman has an increase chance of developing breast, ovarian, and/or uterus cancer.

Sources: http://www.ambrygen.com/tests/ovanext

Marker: ATM, BARD1, BRIP1, CDH1, CHEK2, EPCAM, MLH1, MRE11A, MSH2, MSH6, MUTYH, NBN, PALB2, PMS2, PTEN, RAD50, RAD51C, STK11, and TP53

Organ: Breast, Ovaries, Uterus

Medline Searches: (("breast"[MeSH Terms] OR "breast"[All Fields]) OR ("ovary"[MeSH Terms] OR "ovary"[All Fields]) OR ("uterus"[MeSH Terms] OR "uterus"[All Fields])) AND ("neoplasms"[MeSH Terms] OR "neoplasms"[All Fields]) AND (("Ann Thorac Med"[Journal] OR "atm"[All Fields]) OR BARD1[All Fields] OR BRIP1[All Fields] OR CDH1[All Fields] OR CHEK2[All Fields] OR ("tumor-associated antigen GA733"[Supplementary Concept] OR "tumor-associated antigen GA733"[All Fields] OR "epcam"[All Fields]) OR MLH1[All Fields] OR MRE11A[All Fields] OR MSH2[All Fields] OR MSH6[All Fields] OR MUTYH[All Fields] OR NBN[All Fields] OR PALB2[All Fields] OR PMS2[All Fields] OR PTEN[All Fields] OR RAD50[All Fields] OR RAD51C[All Fields] OR STK11[All Fields] OR TP53[All Fields]) AND "humans"[MeSH Terms]

medline hits= 3067

FDA approved: No

### Gene Test Information: PANEXIA

Test Name: PANEXIA

Description: PANEXIA® detects mutations in genes that result in an increased risk of pancreatic cancer, offering insight about the risk of future hereditary cancers for patients and their families. PANEXIA, via a simple blood test, analyzes the PALB2 and BRCA2 genes, the two genes most commonly identified in families with hereditary pancreatic cancer.

The PANEXIA test results provide information for patients and their family members about the inherited risks of pancreatic cancer as well as breast, ovarian, and other cancers. This knowledge may allow at-risk family members the opportunity to lower their risks for some of these cancers through surveillance, preventative options, or lifestyle choices.

Purpose: Prediction of an increase risk of developing pancreatic and/or breast cancer.

Availability: Myriad Genetics

Specimen: Blood

Methodology: Gene sequencing

Diseases: Pancreatic or/and Breast Cancer

Clinical Uses: To determine if a person has an increase risk of developing pancreatic and/or breast cancer. The test determines the presence of the PALB2 and BRCA2 genes. The results of the test enable the development of a patient-specific medical management plan to reduce the risk of cancer

Sources: www.myriad.com

Marker: PALB2, BRCA2

Organ: Pancreas, Breast

Medline Searches: (PALB2[All Fields] OR ("genes, brca2"[MeSH Terms] OR ("genes"[All Fields] AND "brca2"[All Fields]) OR "brca2 genes"[All Fields] OR "brca2"[All Fields] OR "brca2 protein"[MeSH Terms] OR ("brca2"[All Fields] AND "protein"[All Fields]) OR "brca2 protein"[All Fields])) AND (("pancreatic neoplasms"[MeSH Terms] OR ("pancreatic"[All Fields] AND "neoplasms"[All Fields]) OR "pancreatic neoplasms"[All Fields] OR ("pancreatic"[All Fields] AND "cancer"[All Fields]) OR "pancreatic cancer"[All Fields]) OR ("breast neoplasms"[MeSH Terms] OR ("breast"[All Fields] AND "neoplasms"[All Fields]) OR "breast neoplasms"[All Fields] OR ("breast"[All Fields] AND "cancer"[All Fields]) OR "breast cancer"[All Fields])) AND "humans"[MeSH Terms]

Medline hits=4530

FDA approved: No

### Gene Test Information: PTEN genetic analysis

Test Name: PTEN

Description: Somatic (noninherited) mutations in the PTEN gene are among the most common genetic changes found in human cancers. These mutations are acquired during a person's lifetime and are present only in tumor cells. PTEN gene mutations have been reported in many types of cancer, such as prostate cancer, endometrial cancer, glioblastomas and astrocytomas, and in melanoma. Mutations in the PTEN gene result in an altered protein that has lost its tumor suppressor function. The loss of this protein's function likely permits certain cells to divide uncontrollably, contributing to the growth of cancerous tumors. In some cases, the presence of PTENgene mutations is associated with more advanced stages of tumor growth.

Purpose: Diagnostic, prognosis, and therapeutic management

Availability: Academic and Commercial laboratories

Specimen: Tumor tissue

Methodology: Deletion/duplication analysis; Next generation gene sequencing; Mutation analysis; FISH analysis

Diseases: Multiple cancers including prostate cancer, endometrial cancer, glioblastomas and astrocytomas, and melanoma

Clinical Uses: To detect and type mutations in the PTEN tumor suppressor gene for diagnosis of Cowden disease and Bannayan-Riley-Rucvalcaba syndrome and for prognosis and therapy selection in range of cancer types, particularly endometrial carcinoma, glioblastoma multiforme, melanoma, and prostatic carcinoma.

Sources: www.ghr.nlm.nih.gov/gene/PTEN, www.mdanderson.org

Marker (Medline Search): PTEN

Organ (Medline Search): Cancer or Neoplasms

Medline Searches: pten[All Fields] AND ("neoplasms"[MeSH Terms] OR "neoplasms"[All Fields] OR "cancer"[All Fields])

Medline hits=5396

FDA approved: No

### Gene Test Information: 5-Fluorouracil Sensitivity gene mutations

Test Name: 5-FU sensitivity (DPYD, TYMS, and MTHFR)

Description: 5-fluorouracil (5-FU) is a fluoropyrimidine drug and is the most frequently used chemotherapeutic drug in the treatment of colorectal cancer and other solid tumors. The dihydropryrimidine dehydrogenase (DPD) enzyme, encoded by the DPYD gene, is responsible for the degradation and inactivation of greater than 80 percent of 5-FU. TYMS gene mutations result in reduced expression of TS and may be associated with higher clinical responsiveness to 5-FU therapy and possibly an increased risk of toxicity. Methylenetetrahydrofolate reductase (MTHFR) is involved in the metabolism of folate and forms the reduced folate cofactor needed for TS inhibition.

Purpose: Therapeutic management

Availability: Academic and Commercial Laboratories

Specimen: Tumor tissue

Methodology: Multiplex PCR

Diseases: Colorectal cancer and other solid tumors

Clinical Uses: Genetic variation may contribute to risk of toxicity and/or altered therapeutic benefit

Sources: www.aruplab.com, www.bcm.edu

Marker (Medline Search): Fluorouracil

Organ (Medline Search): MTHFR or TYMS or DPYD

Medline Searches: ("fluorouracil"[MeSH Terms] OR "fluorouracil"[All Fields] OR "5 fluorouracil"[All Fields]) AND (("methylenetetrahydrofolate reductase (nadph2)"[MeSH Terms] OR ("methylenetetrahydrofolate"[All Fields] AND "reductase"[All Fields] AND "(nadph2)"[All Fields]) OR "methylenetetrahydrofolate reductase (nadph2)"[All Fields] OR "mthfr"[All Fields]) OR TYMS[All Fields] OR DPYD[All Fields])

Medline hits=269

FDA approved: No (but labeled for 5-FU)