# Executive Summary

## Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested that the Technology Assessment Program (TAP) of the Agency for Healthcare Research and Quality (AHRQ) conduct an update of genetic tests for cancer conditions that were identified since the 2011 horizon scan report on Genetic Testing for Cancer. AHRQ assigned this project to the Tufts Medical Center Evidence-based Practice Center (Contract Number: HHSA 290 2007 10055 I, Task Order #11).

The main objective of this report is to provide succinct information on each identified genetic test through grey literature search since 2011. The contents in this report reflect the data of genetic tests that were obtained from manufacturers’ Web sites or other commercial Web sites, and should not be considered as verified information or construed as definitive clinical evidence or as recommendations for their routine clinical use.

## Methods

We included genetic tests that have applications in the common solid tumors (breast, lung, colorectal, pancreas, etc.) as well as tests that are used in hematologic cancers (leukemia, lymphoma) and are already available in clinical practice. The population of interest was adults with more applicability to the Medicare age group. We included genetic tests that are performed to aid in diagnosing, treating, predicting, prognosticating, monitor patient status and detect cancer recurrence. We also included genetic tests based on at least one of the following selection criteria:

1. Genetic tests that have been cleared by FDA or pending clearance by FDA.
2. Genetic tests that are conducted in Clinical Laboratory Improvement Amendments (CLIA) certified labs and require a physician order, but may or may not have been cleared by FDA.
3. Genetic tests offered by Internet sites that specifically require a physician order.

We excluded genetic tests that are performed for cancers that occur in early childhood or adolescence and exclusively result in early death before reaching adulthood and tests marketed directly to consumers (direct-to-consumer genetic tests). For this report, we also excluded tests performed to identify noncancer conditions.

Once the list of current genetic tests was identified, one-page summaries of each test were completed using data extracted from various sources, including laboratory Web sites and test manufacturer Web sites. Data included in these summaries are a more detailed description of the test and its clinical use. The following items are included in the one-page summary: Test name, Description, Purpose (such as Diagnostic, Prognostic, Predictive, Recurrence, Monitoring, and Therapeutic), Availability, Specimen, Diseases, Clinical uses, Source, Marker (Medline Search Terms), Organ (Medline Search Terms), and Exploratory PubMed search.

The horizon scanning has been ongoing as a continuous process since 2005 and the reports were continuously updated until January 2013. The results of grey literature along with one-pagers have been updated weekly. The relevance of the genetic tests was verified at the time of preparation of this report.

## Results

We identified 44 new genetic tests for 10 common cancer conditions since the 2011 report, with the largest number of tests being utilized for breast cancer (18 genetic tests). Additionally we added 22 new tests that were identified during peer and public review process. All 44 new genetic tests that we identified were through internet searches alone. Recent grey literature searches indicate that the largest numbers of new tests were found in the breast cancer category. The one-page description for these newly identified genetic tests for cancer conditions can be found in Appendix A. Of the tests that were identified as tests in our previous reports, the following five tests are excluded for the following reasons: One test (PyloriProbe) has been voluntarily withdrawn from the market, two tests that were identified as those used in the context of aspiration of cervical or breast specimens, one test identified as evaluating genetic material of infectious agent (digene High-Risk HPV HC2 DNA Test), one test (PreGen Plus) has also been withdrawn voluntarily from the market, and one test (OvaSure) identified by our 2011 report has been withdrawn from the market.

## Discussion

Since 2011, a total of 66 new genetic tests available for clinical use in 10 common cancer conditions. This report of updating genetic tests for cancer conditions adds potentially important information on emerging tests that are in clinical use. The current report is a valuable source of genetic tests that are in clinical use with specific applicability to older adults. In addition, the yield from this report has helped us to generate topics for conducting systematic reviews of emerging genetic tests. Genetic testing is a rapidly evolving field with the potential to dramatically influence clinical decision-making. Health care providers, patients, payers, decision-makers, and consumers can benefit from staying abreast of newly-released tests.