# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Diane Allingham-Hawkins, PhD, FCMG, FACMG
  Senior Director, Genetic Test Evaluation and Technical Editing
  Hayes, Inc.
  Lansdale, Pennsylvania
- Linda A. Bradley, MD
  Associate Director, Division of Medical Screening and Special Tests
  Women & Infants Hospital Rhode Island
  Providence, Rhode Island
- Marta Gwinn, MD, MPH
  Senior Epidemiologist Consultant
  McKing Consulting Corporation
  Atlanta, Georgia