# References

1 Khoury MJ, Dorman JS. The Human Genome Epidemiology Network. Am J Epidemiol. 1998;148:1-3. [pmid: 9663396].
2 Khoury MJ, Millikan R, Little J, Gwinn M. The emergence of epidemiology in the genomics age. Int J Epidemiol. 2004;33:936-944. [pmid: 15319400].
3 Chin KM, Wessler B, Chew P, Lau J. Genetic Tests for Cancer. Evidence Report/Technology Assessment. 2006. Access Date: 6/1/13. http://archive.ahrq.gov/clinic/ta/gentests/.
4 Thorn CF, Klein TE, Altman RB. PharmGKB: the pharmacogenetics and pharmacogenomics knowledge base. Methods Mol Biol. 2005;311:179-191. [pmid: 16100408].
5 Gwinn M, Grossniklaus DA, Yu W, Melillo S, Wulf A, Flome J, et al. Horizon scanning for new genomic tests. Genet Med. 2011;13:161-165. [pmid: 21233720].
6 Dahabreh IJ, Terasawa T, Castaldi PJ, Trikalinos TA. Systematic review: Anti-epidermal growth factor receptor treatment effect modification by KRAS mutations in advanced colorectal cancer. Ann Intern Med. 2011;154:37-49. [pmid: 21200037].
7 Raman G, Trikalinos TA, Zintzaras E, Kitsios G, Ziogas D, Ip S, Lau J. Reviews of Selected Pharmacogenetic Tests for Non-Cancer and Cancer Conditions. 2008. Access Date: 6/1/13. http://www.cms.gov/Medicare/Coverage/DeterminationProcess/downloads//id61TA.pdf.
8 Terasawa T, Dahabreh I, Trikalinos TA. BCR-ABL mutation testing to predict response to tyrosine kinase inhibitors in patients with chronic myeloid leukemia. PLoS Curr. 2010;2:RRN1204. [pmid: 21188137].
9 Kuehn BM. NIH launching genetic test registry. JAMA. 2010;303:1685. [pmid: 20442379].
10 Rubinstein WS, Maglott DR, Lee JM, Kattman BL, Malheiro AJ, Ovetsky M, et al. The NIH genetic testing registry: a new, centralized database of genetic tests to enable access to comprehensive information and improve transparency. Nucleic Acids Res. 2013;41:D925-D935. [pmid: 23193275].