# Results

In the following sections, we detail the results of the analysis of PET for patients who may have AD. The presentation is organized by three scenarios defined by patient presentation: Scenario A – mild to moderate dementia; Scenario B – mild cognitive impairment; and Scenario C – asymptomatic but with a first-degree relative with AD.

## Scenario A: Mild to moderate dementia

### What are the possible clinical management options and outcomes for this scenario?

Individuals who present with documented dementia and who do not have evidence of a non-AD etiology of their condition are candidates for treatment with AChE-I medications (Knopman, DeKosky, Cummings, et al., 2001) as well as other supportive interventions for patient, family/caregivers (Marriott, Donaldson, Tarrier, et al., 2000; Mittelman, Ferris, Shulman, et al., 1996). Because treatment has been demonstrated in clinical trials to be effective and is relatively well tolerated by most patients with AD dementia, AChE-I treatment for all patients with mild to moderate dementia is common practice (See below: “What are the benefits and adverse effects of AChE-I therapy when used for patients in the scenario?”). This strategy of treating all patients with a diagnosis of AD after a standard work-up is denoted in this section as “Treat All”. A second possible strategy is to test with PET and to treat only those individuals with results consistent with AD (denoted “Test”). The third possible strategy to consider is to not test or treat (denoted “No Test/No Treat”).

Categories of outcomes include physical outcomes, psychological outcomes, legal outcomes, and ethical outcomes. Costs are not considered explicitly. Physical outcomes include life expectancy, quality-adjusted life expectancy, and severe dementia-free life expectancy. In the decision model the psychological, legal, and ethical domains are represented by the surrogate measures – proportion of patients falling into the 4 categories: (1) true positive (with AD and treated), (2) false positive (without AD and treated), (3) true negative (without AD and not treated) and (4) false negative (with AD and not treated). We also considered correct diagnoses (true positives plus true negatives).

Note that when considering the impact of treatment, we consider only AChE-I therapy, as the appropriateness of all other treatments such as vitamin E, medications for symptom relief, and psychosocial interventions does not depend on the specific diagnosis of AD.

### What is the diagnostic performance of PET in this scenario?

Ideally, we should base our estimates of the diagnostic performance of FDG-PET on studies that test its ability to distinguish AD from other causes of dementia among representative samples of patients presenting with dementia. However, available data in the literature far more frequently describes the ability of FDG-PET to distinguish AD from normal control subjects. Such studies can be expected to overestimate the diagnostic performance of FDG-PET.

We describe first the few studies that describe discrimination between AD and non-AD dementia and second the majority of studies which describe discrimination of AD from normal control subjects.

Three studies describe the ability of FDG-PET to discriminate patients with AD from those with other causes of dementia (Salmon 1994); Hoffman 2000; Silverman 2001).

Salmon et al.( Salmon, Sadzot, Maquet, et al., 1994) included patients with mild, moderate and severe dementia. Sixteen of 65 AD patients had mild dementia and 25 AD patients had moderate dementia. For 64 non-AD dementia control patients, the severity of dementia was not described. While AD diagnoses were based on NINCDSADRA criteria, the basis for non-AD dementia diagnoses was not described. In the overall study population, which included patients with severe dementia, operating characteristics of FDG-PET for distinguishing AD from vascular dementia included sensitivity of 86% and specificity of 61%. This study described results stratified by severity of dementia only for patients with AD, permitting calculation of sensitivity for three subsets of patients: sensitivity of FDG-PET was 75% for patients with mild AD, 88% for patients with moderate AD, and 92% for patients with severe AD. While a trend in the point estimates appears to be present, the number of subjects is too small for these differences to be statistically significant.

Hoffman et al did not describe the severity of dementia in the study population. They used histopathology as their reference standard. This reference standard is more definitive than the standard clinical evaluation used by most other studies. The resulting analysis give sensitivity of 88% and specificity of 67%, results very close to the figures for Salmon, Sadzot, Maquet, et al., 1994.

Silverman et al recently reported a large study of FDG-PET for diagnosis of AD versus other causes of dementia (Silverman, Small, Chang, et al., 2001). This study reports on two populations, a prospective cohort of patients that received long-term clinical follow-up and a retrospective cohort of patients with a histopathological reference standard. In addition, the study reported an association between PET results and progression of disease, an outcome not assessed by previous studies. Among patients with a histopathological diagnosis, the sensitivity of FDG-PET for diagnosing AD was 94% (91/97; 95% CI, 89% to 99%) and the specificity was 73% (30/41; 95% CI, 60% to 87%). In the subset of patients with questionable or mild dementia at the time of PET, the diagnostic performance was similar: sensitivity 95% (89% to 100%) and specificity 71% (48% to 95%).

These three studies provide estimates for the sensitivity and specificity of FDG-PET in distinguishing AD from non-AD dementia. They are few in number and somewhat variable, with sensitivity ranging from 86% to 95% and specificity ranging from 61% to 74%.

In addition to these three studies there were five studies that describe the operating characteristics of PET in discriminating between patients with dementia due to AD and specific etiologies of non-AD dementias: multi-infarct dementia (Duara, Barker, Lowenstein et al., 1989), vascular dementia (Mielke, Pietrzyk, Jacobs, et al., 1994; Szelies, Mielke, et al., 1994) and dementia with Lewy bodies (Ishii, Imamura, Yamaji, et al., 1998; Higuchi, Tashiro, Arai, et al., 2000). In these studies the sensitivity of PET ranged from 88%–90% and the specificity ranged from 18%–86%.

To further investigate the variability of PET diagnostic data and to provide additional data for the model estimates, we also analyzed studies that describe discrimination between patients with AD and normal controls.

Fifteen studies compared patients with AD at different stages of dementia to normal controls (Azari, Pettigrew, Schapiro, et al., 1993; Burdette, Minoshima, Vander Borght, et al., 1996; Duara, Barker, Loewenstein, et al., 1989; Fazekas, Alavi, Chawluk, et al., 1989; Grady, Haxby, Schapiro, et al., 1990; Herholz, 1990; Herholz, Perani, Salmon, et al., 1993; Higuchi, Tashiro, Arai, et al., 2000; Ishii, Imamura, Sasaki, et al., 1998; Kippenhan, Barker, Pascal, et al., 1992; Messa, Perani, Lucignani, et al., 1994; Mielke, Pietrzyk, Jacobs, et al., 1994; Minoshima, Frey, Foster, et al., 1995; Ohyama, Senda, Mishina, et al., 2000; Szelies, Mielke, Herholz, et al., 1994).

Table 8 summarizes the characteristics of the principal study subjects and the operating characteristics for PET from these studies.

Five studies did not explicitly report sensitivity and specificity values. Four of these studies provided plots of metabolic ratio for patients with AD and controls (Herholz, Perani, Salmon, et al., 1993; Higuchi, Tashiro, Arai, et al., 2000; Ishii, Imamura, Sasaki, et al., 1998; Mielke, Pietrzyk, Jacobs, et al., 1994). A fifth study presented the ROC curves for the test (Kippenhan, Barker, Pascal, et al., 1992). For these studies we decided to use a cut-off point value of 90% for the specificity, which allowed us to estimate the specificity from the plots or ROC curves. Specificity estimates in these five studies ranged from 17% to 85%.

For the other ten studies that provided sensitivity and specificity estimates, sensitivity ranged from 61% to 100%, and specificity from 54% to 100.

A meta-analysis was performed with “Meta-Test” version 0.6. For this analysis, the five studies that did not explicitly report sensitivity and specificity were excluded. The remaining studies demonstrated heterogenous estimates of sensitivity and specificity. For these remaining studies, a random effects model was used (Figure 2) producing a pooled sensitivity estimate (95% CI) for distinguishing normal healthy controls from patients with AD of 88% (79% to 94%), and a pooled specificity estimate of 87% (77% to 93%).

### What are the benefits and adverse effects of AChE-I therapy when used for patients in this scenario?

As described in the “Introduction”, practice guidelines recommend treating AD patients with currently available and approved AChE-I medications: donepezil (Aricept), rivastigmine (Exelon) or galantamine (Reminyl)(Doody, Stevens, Beck, et al., 2001). In multiple RCTs, AChE-I agents have been shown to delay the onset of progression by approximately 6 months. [RCT evidence] (Doody, Stevens, Beck, et al., 2001). Approximately 10–20% of patients are unable to tolerate therapy due to minor, transient side effects primarily leading to drug discontinuation (Burns, Rossor, Hecker, et al., 1999; Birks and Flicker 2001). As detailed in “Methods”, the approach we took to converting trial results to an estimate of treatment effect on probability of progression of disease translates to a relative risk of progression of 0.72.

### For a patient with dementia which strategy is most likely to provide better health outcomes?

For scenario A the decision model was applied separately to a moderate dementia cohort and a mild dementia cohort. Since results for both cohorts were substantively similar and the results for mild dementia patients were more favorable to PET scanning (Table 9a), we limit our presentation here to patients with mild dementia.

Base-case analysis: In the base case, “Treat All” is preferred over either “Test” or “No Test/No Treat”, in terms of quality-adjusted life expectancy (Table 9a), life expectancy, or severe-dementia-free life expectancy. The “Test” strategy is preferred only by the measure “percentage correct diagnosis” (proportion of patients who are true positive or true negative).

One-way sensitivity analyses: The relative preference for the three strategies is unaffected by changing the following input values over their plausible range: PET sensitivity or specificity, prevalence of AD, effectiveness of treatment, duration of treatment effectiveness, percentage of complications or discount rate. However, when treatment complications are equivalent to mortality, treating all patients becomes the least preferred strategy.

Hypothetical treatments with onerous complications: Sensitivity analysis suggests that while the “Treat All” strategy is optimal when treatment is relatively benign and at least modestly effective, the strategy becomes less attractive when treatment complications loom large enough to become more equivalent to mortality. To further explore the impact of treatment complications on preferred strategy, we considered several hypothetical treatments characterized by a variety of negative characteristics. These include a treatment with long-term effects manifest as either a decrease in utility (50% reduction in utility for 1 year or 20% reduction in utility for a lifetime), an increase in rate of progression of disease (relative risk for progression of 2 for 1 year), or an increase in the mortality rate (relative risk for death of 5 for 1 year).

All hypothetical treatments considered within this sensitivity analysis lead to “Test” being preferred in terms of either quality-adjusted life expectancy or severe dementia-free life expectancy (Table 9a). Since one would not choose a therapy that was as efficacious as AChE-I but had worse complications, we performed a two-way analysis to examine the interaction between treatment efficacy (in terms of relative risk of progression) and change in quality of life with treatment (in terms of utility change relative to the utility for mild dementia). We did this by varying widely the values of these two inputs, and by plotting the territories on the efficacy/ complication utility plane in which one strategy is preferred over others. These results are shown in Figure 3. As noted in one-way sensitivity analysis, this figure reveals that “Test” becomes more attractive as utility with complications becomes worse (one moves down the plane). However, if efficacy is simultaneously increased (one moves towards the left on the plane) “Test” becomes less attractive. This observation indicates that the optimal strategy in the face of a treatment with more onerous complications cannot be predicted without also knowing the concomitant improvement in effectiveness. It should be noted here that the relative benefit of “Test” is at a maximum of 0.03 QALYs (11 days) when the hypothetical treatment has a complication with a utility equivalent to death.

## Scenario B: Mild cognitive impairment

### What are the possible clinical management options and outcomes for this scenario?

Individuals presenting with mild cognitive impairment but without the functional impairment required for the diagnosis of dementia are often treated with AChE-I. However the evidence for this practice is lacking (as noted below in “What are the benefits and adverse effects of AChE-I therapy when used for patients in the scenario?”). If the evidence for AChE-I medication effectiveness can be extrapolated to the MCI population, the rationale for AChE-I treatment is that delaying the onset of dementia is even more valuable than delaying the onset of severe dementia for those already experiencing mild to moderate functional impairment and that MCI patients are very likely to progress to dementia. Indeed, it appears that the proportion of MCI patients with AD is greater than the proportion of demented patients with AD (Mohs, Breitner, Silverman, et al., 1987; Morris, McKeel, Storandt, et al., 1991). As with Scenario A, three major management strategies are possible for individuals with MCI. The first is to treat based on clinical findings (“Treat All”). The second is to test with PET and to treat only those individuals with PET results consistent with AD (“Test”). The third is to not treat (“No Test/No Treat”).

Clinical outcomes considered include life expectancy, quality-adjusted life expectancy, dementia-free life expectancy, and proportion of patients falling into the 4 categories, true positive (with AD and treated), false positive (without AD and treated), true negative (without AD and not treated) and false negative (with AD and not treated). We also considered proportion of patents with true diagnoses (true positive plus true negative).

### What is the diagnostic performance of PET in this scenario?

Only two studies provided sub-group analysis by degree of dementia. Burdette et al. divided their population of patients with AD into two groups (Burdette, Minoshima, Vander Borght, et al., 1996). In the group of 28 patients with questionable or mild dementia the sensitivity of PET was 79%. The sensitivity was 100% in the group of 11 patients with moderate to severe dementia (MMSE < 15). In another study, Fazekas et al. reported a sensitivity of 100% for patients with mild to moderate dementia (MMSE > 15) and of 93% for patients with moderate to severe dementia (MMSE < 15) (Fazekas, Alavi, Chawluk, et al., 1989).

These data, along with the data on difference in performance by dementia severity described previously, suggest that diagnostic performance of FDG-PET may be less accurate for less severe forms of AD. However, because there is no data among subjects with MCI, we use the conservative assumption that diagnostic performance is the same as that in mild-moderate dementia.

### What are the benefits and adverse effects of AChE-I therapy when used for patients in this scenario?

No trials were identified for the use of AChE-I drugs or other treatments in MCI patients.

### For a patient with mild cognitive impairment, which strategy is most likely to provide better health outcomes?

Table 9b presents the results for the base case and sensitivity analysis for patients with MCI. The results are substantively the same as for Scenario A. Again, the “Treat All” strategy is preferred in the base case, except by the measure of “proportion correct diagnosis”. The base case results are robust by sensitivity analysis, although hypothetical treatments with especially bad consequences would cause “Test” to become preferred. Also, as with Scenario A, the two-way analysis examining the impact of changes in treatment efficacy concurrent with a decline in utility for patients with complications reveals that a treatment that has both greater efficacy and more onerous complications can lead to “Test” being less preferred (Figure 4).

## Scenario C: Asymptomatic with a first-degree relative with AD

### What are the possible clinical management options and outcomes for this scenario?

Unlike Scenarios A and B, treatment with AChE-I medications is neither recommended nor common. Like Scenario B, there is no evidence that individuals at an elevated risk will benefit from such treatment by a delayed progression of disease (see below: “What are the benefits and adverse effects of AChE-I therapy when used for patients in the scenario?”). However, the current hypothesis is t is hypothesized that for patients who are destined to manifest AD, treatment can delay the progression. Thus, we evaluated the same management strategies for asymptomatic, high-risk individuals as for symptomatic individuals: treat preemptively (“Treat All”), test with PET, and treat only those individuals with results consistent with AD (“Test”), and neither test nor treat (“No Test/No Treat”).

Categories of outcomes include physical outcomes, psychological outcomes, legal outcomes, and ethical outcomes. Costs were not considered explicitly. Physical outcomes include life expectancy, quality-adjusted life expectancy, and dementia-free life expectancy. In the decision model the psychological, legal, and ethical domains were represented by the surrogate measures: proportion of patients falling into the four categories, true positive (with AD and treated), false positive (without AD and treated), true negative (without AD and not treated) and false negative (with AD and not treated). We also considered correct diagnoses (true positives plus true negatives).

### What is the diagnostic performance of PET in this scenario?

No studies exploring the use of PET in asymptomatic at risk patients satisfied our inclusion criteria for abstraction.

### What are the benefits and adverse effects of AChE-I therapy when used for patients in this scenario?

No trials were identified for the use of AChE-I drugs or other treatments in asymptomatic individuals at an elevated risk for AD.

### For an asymptomatic patient with a family history of AD, which strategy is most likely to provide better health outcomes?

Base-case analysis: For asymptomatic high-risk individuals, the “Treat All” strategy is preferred in terms of life expectancy, quality-adjusted life expectancy, and dementia-free life expectancy (Table 9c). The “Test” strategy is second, except for the proportion of patients with correct diagnosis; as with the symptomatic scenarios, the “Test” strategy leads to the highest proportion of true positives plus true negatives.

Sensitivity analyses: As with the symptomatic scenarios, the preference for “Treat All” is robust for all variations of the following inputs over their plausible ranges: PET sensitivity or specificity, prevalence of AD, efficacy of treatment, duration of treatment, probability of treatment complications or discount rate. In all one-way sensitivity analyses, “Test” is consistently the second preferred strategy. When complications are treated like an event (death or progression), the “No Treat” strategy is preferred.

Hypothetical treatments with onerous complications: The effect of hypothetical treatments with especially onerous complications was not as consistent as with the symptomatic scenarios (Table 9c). For patients in Scenario C testing would be preferred only for complications that reduce utility by 50% for 1 year, or by 20% for a lifetime. The “Treat All” strategy is the preferred strategy if complications are modeled as leading either to increased risk of progression to dementia or to an increased risk of death. As with the two-way sensitivity analysis results for scenarios A and B, a severe short-term disutility tends to make “Test” more attractive, but this effect is strongly modulated by the effectiveness of the new treatment. As effectiveness improves, “Test” may become less preferred (Figure 5). It is notable that the territory of the treatment efficacy/complication utility plane appears wider for scenario C as compared to scenarios A and B. This is in part because the rate of progression in asymptomatic patients is quite slow so that true positive (more likely in the “Treat” strategy) becomes less important and true negative (more likely in the “Treat” strategy) becomes relatively more important. To clarify this, we performed a sequence of 3 one-way sensitivity analyses, each analysis for a different level of treatment efficacy (Figure 5b, 5c, and 5d, correspond to a relative risk for progression with treatment of 0.8, 0.5, and 0.3, respectively). The maximum relative benefit of “Test” is 0.037 QALYs (14 days) when the hypothetical treatment has an efficacy of approximately 0.8 (a treatment not as efficacious as that for an AChE-I) and a complication utility value of approximately 0.35 As seen in Figures 5c and 5d, the relative benefit of testing attains a maximum value for QALYs only when a treatment is effective enough to decrease the rate of disease progression by a factor of 0.5. It attains a maximum value of 15 days when the treatment decreases the rate of progression by a factor of 0.3 and when complications are equivalent to mortality.

### What are the legal, ethical and psychosocial impacts of receiving a dementia diagnosis for individuals best represented by one of the three scenarios?

In patients with mild to moderate dementia the decision analysis provides an assessment of the impact of PET in terms of improvement in cognition and freedom from treatment complications. Issues not directly addressed include the legal, ethical, and psychosocial impact of receiving a diagnosis of AD, whether correct or incorrect, or of failing to be treated as AD.

The entire concept of an ethical, psychosocial or legal impact of testing or not testing is based on the state of the disease that the patient is in at the current time and the possibility of the progression of the disease. There have been studies that deal with various aspects of testing and its impact on individuals and their families – the aspects of autonomy, maleficence, the three forms of beneficence, justice (especially distributive justice), liability and the effects on employability and insurance. The impacts of testing appear to affect individuals in Scenarios B and C (mild cognitive impairment and asymptomatic high-risk), more than those in Scenario A (mild and moderate dementia). Table 10 illustrates some of the salient points.

Table 8 Studies exploring the operating characteristics of PET for differentiating patients with AD from normal controls

Study | AD population | Controls | PET characteristics | Operating Characteristics TP FN FP TN Sens Spec | Quality Score | No. in SROC curve
Azari et al. 1993, data collection dates NR Bethesada (NIH), Maryland | 19, 10 with mild dementia, 19 with moderate dementia Age (range): 52–81 | 22 healthy controls Age (range): 53–75 | Scanner: Scanditronix PC1024-7B Criteria for positivity: fronto-parietal hypometabolism | 18 1 1 20 95% 95% | 1 | 6
Burdette et al. 1996, data collection 1989–92 Ann Arbor, Michigan | 39, 28 with MCI or mild dementia, 11 with moderate/severe dementia Mean ± SD age: 68 ± 7.6 | 22 healthy controls Mean ± SD age: 64 ± 7.5 | Scanner: 931/08-12 CTI Criteria for positivity: symmetrical parietotemporal hypometabolism | 33 6 5 35 85% 88% | 5 | 1
Duara et al. 1989, data collection dates NR Miami Beach, Florida | 50 Mean ± SD age: 72.8 ± 9.7 | 20 young healthy controls, Mean ± SD age: 41.5 ± 9.9 41 older healthy controls, Mean ± SD age: 67.2 ± 8.9 | Scanner: PETT V Criteria for positivity: hypometabolism index | 44 6 10 19 88% 66% 44 6 19 22 88% 54% | 5 | 2
Fazekas et al. 1989, data collection dates NR Philadelphia, Pennsylvania | 30, 14 with mild/moderate dementia, 16 with moderate/severe dementia Mean age: 65 | 25 age-matched controls Mean age: 65 | Scanner: PETT V Criteria for positivity: any hypometabolism | 27 1 4 21 96% 84% | 5 | 5
Grady et al. 1990, data collection dates NR Bethesda, Maryland | 33 Mean ± SD age: 68.5 ± 9.5 | 41 healthy controls Mean ± SD age: 64.9 ± 10.9 | Scanner: Scanditronix PC1024-7B Criteria for positivity: parieto-temporal hypometabolism, controls all considered as negative | 20 13 0 41 61% 100% | 3 | 3
Herholz et al. 1990, data collection dates NR Köln, Germany | 19 Mean ± SD age: 60.6 ± 7.1 | 19 healthy controls Mean ± SD age: 61.1 ± 10.2 | Scanner: Scanditronix PC-384 Criteria for positivity: any hypometabolism | 19 0 0 19 100% 100% | 2 | 8
Herholz et al. 1993, data collection dates NR Germany, Italy, Belgium | 37 Mean ± SD age: 65.2 ± 7.4 | 34 healthy controls Mean ± SD age: Italy 44.6 ± 15.7, Belgium 58.2 ± 8.0, Germany 65.4 ± 7.3 | Scanner: Italy Ecat 931/04-12, Belgium NeuroEcat, Germany Scanditronix PC-384 Criteria for positivity: not reported. A cut-off point at which sensitivity is 90% was chosen by the reviewers | 33 4 5 28 89% 85% | 1 | X
Higuchi et al. 2000, data collection dates NR Sendai, Japan | 11 Mean ± SD age: 66.5 ± 5.7 | 10 normal controls Mean ± SD age: 65.0 ± 8 | Scanner: SET2400W, Shimadzu Criteria for positivity: metabolic ratio. A cutoff point at which sensitivity is 90% was chosen by the reviewers | 10 1 7 3 91% 30% | 2 | X
Ishii et al. 1998, data collection dates NR Himeji, Japan | 12 Mean ± SD age: 73.2 ± 6.3 | 12 normal controls Mean ± SD age: 72.8 ± 4.9 | Scanner: Headtome IV, Shimadzu Criteria for positivity: any hypometabolism. A cut-off point at which sensitivity is 90% was chosen by the reviewers | 11 1 10 2 92% 17% | 3 | X
Kippenham et al. 1992, data collection dates NR Miami, Florida | 41 Mean ± SD age: 70.9 ± 8.8 | 50 normal controls Mean ± SD age: 67.7 ± 8.9 | Scanner: PETT V Criteria for positivity: any deficit present. A cut-off point at which sensitivity is 90% was chosen by the reviewers | 37 4 15 35 90% 70% | 2 | X
Messa et al. 1994, data collection dates NR Milan, Italy | 21 Mean ± SD age: 62.8 ± 7.8 | 10 normal controls Mean ± SD age: 47 ± 13 | Scanner: 931/04-12 CPS/Siemens Criteria for positivity: out of mean ± 2 SD | 21 0 1 9 100% 90% | 1 | 10
Mielke et al. 1994, data collection dates NR Köln, Germany | 10 Mean ± SD age: 68.8 ± 5.6 | 13 normal controls Mean ± SD age: 59.5 ± 11.1 | Scanner: ECAT, Siemens Criteria for positivity: metabolic ratio. A cutoff point at which sensitivity is 90% was chosen by the reviewers | 18 2 5 8 90% 62% | 2 | X
Minoshima et al. 1995, data collection 1989–92 Ann Arbor, Michigan | 37 Mean ± SD age: 64 ± 8 | 22 normal controls Mean ± SD age: 68 ± 7 | Scanner: ECAT, Siemens Criteria for positivity: glucose metabolic rate in parieto-temporal cortex | 36 1 0 22 97% 100% | 4 | 4
Ohyama et al. 2000, data collection dates NR Tokyo, Japan | 21 Mean ± SD age: 61 ± 10 | 10 normal controls Mean ± SD age: 55 ± 12 | Scanner: Headtome IV Criteria for positivity: any hypometabolism | 18 3 1 9 86% 90% | 5 | 9
Szelies et al. 1994, data collection dates NR Köln, Germany | 24, 14 patients with mild dementia, 10 patients with moderate dementia Mean ± SD age: 65.9 ± 7.6 | 15 normal controls Mean ± SD age: 60 ± 7.3 | Scanner: Scanditronix 384 Criteria for positivity: metabolic ratio | 18 6 5 10 75% 67% | 2 | 7

TP = True Positive, FN = False Negative, FP = False Positve, TN = True Negative

Table 9a Results- Mild dementia

(QALY=Quality of life, LE=Life expectancy, SDFLE=Severe dementia free life expectancy)

OUTCOMES
| QALY | LE | SDFLE | True Positives | False Positives | False Negatives | True Negatives | Percentage correct diagnosis
Base Case Treat all Test No test/No treat | 4.099 4.0902 4.024 | 7.890 7.881 7.818 | 4.015 3.996 3.862 | 0.560 0.490 0.000 | 0.440 0.060 0.000 | 0.000 0.070 0.560 | 0.000 0.380 0.440 | 56% 87% 44%
Sensitivity Analyses
PET sensitivity low = 0.79 Treat all Test No test/No treat | 4.099 4.083 4.024 | | 4.015 3.983 3.862
PET sensitivity high = 0.94 Treat all Test No test/No treat | 4.099 4.095 4.024 | | 4.015 4.006 3.862
PET specificity low = 0.73 Treat all Test No test/No treat | 4.099 4.090 4.024 | | 4.015 3.996 3.862
PET specificity high = 0.93 Treat all Test No test/No treat | 4.099 4.090 4.024 | | 4.015 3.996 3.862
Prevalence AD low = 50% Treat all Test No test/No treat | 4.091 4.083 4.024 | | 3.998 3.982 3.8618
Prevalence AD high = 85% Treat all Test No test/No treat | 4.138 4.125 4.024 | | 4.094 4.066 3.862
Prevalence AD=0% Treat all Test No test/No treat | 4.024 4.024 4.024 | | 3.862 3.862 3.862
Prevalence AD=100% Treat all Test No test/No treat | 4.159 4.143 4.024 | | 4.135 4.102 3.862
RR progression=0 Treat all Test No test/No treat | 4.396 4.352 4.024 | | 4.585 4.499 3.862
RR progression = 0.5 Treat all Test No test/No treat | 4.160 4.144 4.024 | | 4.135 4.102 3.862
RR progression = 1 Treat all Test No test/No treat | 4.024 4.024 4.024 | | 3.862 3.862 3.862
Length of efficacy = 12 months Treat all Test No test/No treat | 4.077 4.071 4.024 | | 3.966 3.953 3.862
Length of efficacy = lifetime Treat all Test No test/No treat | 4.276 4.246 4.024 | | 4.445 4.375 3.862
Treatment complications = 0% Treat all Test No test/No treat | 4.113 4.102 4.024 | | 4.042 4.021 3.862
Treatment complications = 30% Treat all Test No test/No treat | 4.086 4.078 4.024 | | 3.988 3.973 3.862
Treatment complications =100% Treat all Test No test/No treat | 4.024 4.024 4.024 | | 3.862 3.862 3.862
Discount rate = 0% Treat all Test No test/No treat | 4.709 4.698 4.619 | | 4.384 4.363 4.208
Discount rate 5% Treat all Test No test/No treat | 3.773 3.765 3.705 | | 3.803 3.786 3.663
Complications = death Treat all Test No test/No treat | | 6.791 7.277 7.812 | 3.510 3.719 3.862
HYPOTHETICAL SCENARIOS
50% short-term decrease in utility Treat all Test No test/No treat | 4.055 4.066 4.024
20% lifetime decrease in utility Treat all Test No test/No treat | 3.994 4.032 4.024
RR for progression = 2 Treat all Test No test/No treat | 4.039 4.057 4.024 | | 3.898 3.932 3.862
RR for death = 5 Treat all Test No test/No treat | 4.060 4.068 4.024 | | 3.973 3.973 3.862

Table 9b Results- MCI

(QALY=Quality of life, LE=Life expectancy, DFLE=Dementia free life expectancy)

OUTCOMES
| QALY | LE | SDFLE | True Positives | False Positives | False Negatives | True Negatives | Percentage correct diagnosis
Base Case Treat all Test No test/No treat | 6.660 6.650 6.577 | 10.225 10.216 10.149 | 5.614 5.592 5.431 | 0.800 0.700 0.000 | 0.200 0.030 0.000 | 0.000 0.100 0.800 | 0.000 0.170 0.200 | 80% 87% 20%
Sensitivity Analyses
PET sensitivity low = 0.79 Treat all Test No test/No treat | 6.660 6.643 6.577 | | 5.614 5.576 5.431
PET sensitivity high = 0.94 Treat all Test No test/No treat | 6.660 6.655 6.577 | | 5.614 5.603 5.431
PET specificity low = 0.73 Treat all Test No test/No treat | 6.660 6.650 6.577 | | 5.614 5.592 5.431
PET specificity high = 0.93 Treat all Test No test/No treat | 6.660 6.650 6.577 | | 5.614 5.592 5.431
Prevalence AD low = 0% Treat all Test No test/No treat | 6.577 6.577 6.577 | | 5.431 5.431 5.431
Prevalence AD low = 70% Treat all Test No test/No treat | 6.645 6.641 6.577 | | 5.591 5.572 5.431
Prevalence AD high = 100% Treat all Test No test/No treat | 6.681 6.668 6.577 | | 5.660 5.632 5.431
RR progression = 0(treatment is 100% effective) Treat all Test No test/No treat | 6.965 6.918 6.577 | | 6.319 6.213 5.431
RR progression = 0.5 Treat all Test No test/No treat | 6.725 6.707 6.577 | | 5.761 5.721 5.431
RR progression = 1 Treat all Test No test/No treat | 6.577 6.577 6.577 | | 5.431 5.431 5.431
Length of efficacy = 12 months Treat all Test No test/No treat | 6.633 6.626 6.577 | | 5.559 5.544 5.431
Length of efficacy = lifetime Treat all Test No test/No treat | 7.120 7.041 6.577 | | 6.265 6.149 5.431
Treatment complications = 0% Treat all Test No test/No treat | 6.675 6.663 6.577 | | 5.646 5.621 5.431
Treatment complications = 30% Treat all Test No test/No treat | 6.646 6.637 6.577 | | 5.582 5.564 5.431
Treatment complications = 100% Treat all Test No test/No treat | 6.577 6.577 6.577 | | 5.431 5.431 5.431
Discount rate = 0% Treat all Test No test/No treat | 8.116 8.103 8.003 | | 6.578 6.552 6.359
Discount rate 5% Treat all Test No test/No treat | 5.930 5.922 5.861 | | 5.117 5.097 4.952
Complications = death Treat all Test No test/No treat | | 9.485 9.676 10.149 | 4.874 5.052 5.431
50% short-term decrease in utility Treat all Test No test/No treat | 6.608 6.612 6.577
20% lifetime decrease in utility Treat all Test No test/No treat | 6.478 6.517 6.577
RR for progression = 2 Treat all Test No test/No treat | 6.620 6.618 6.577 | | 5.513 5.518 5.431
RR for death = 5 Treat all Test No test/No treat | 6.596 6.603 6.577 | | 5.557 5.551 5.431

Table 9c Results- Asymptomatic elevated risk

(QALY=Quality of life, LE=Life expectancy, DFLE=Dementia free life expectancy)

OUTCOMES
| QALY | LE | DFLE | True Positives | False Positives | False Negatives | True Negatives | Percentage correct diagnosis
Base Case Treat all Test No test/No treat | 12.248 12.231 12.106 | 12.786 12.776 12.707 | 12.206 12.185 12.032 | 0.500 0.440 0.000 | 0.500 0.600 0.000 | 0.000 0.060 0.500 | 0.000 0.440 0.500 | 50% 88% 50%
Sensitivity Analyses
PET sensitivity low = 0.79 Treat all Test No test/No treat | 12.248 12.218 12.106 | | 12.206 12.170 12.032
PET sensitivity high = 0.94 Treat all Test No test/No treat | 12.248 12.240 12.106 | | 12.206 12.196 12.032
PET specificity low = 0.73 Treat all Test No test/No treat | 12.248 12.231 12.106 | | 12.206 12.185 12.032
PET specificity high = 0.93 Treat all Test No test/No treat | 12.248 12.231 12.106 | | 12.206 12.185 12.032
Prevalence AD low = 0% Treat all Test No test/No treat | 12.106 12.106 12.106 | | 12.032 12.032 12.032
Prevalence AD low = 30% Treat all Test No test/No treat | 12.191 12.181 12.106 | | 12.136 12.124 12.032
Prevalence AD high = 70% Treat all Test No test/No treat | 12.305 12.277 12.106 | | 12.276 12.242 12.032
Prevalence AD high = 100% Treat all Test No test/No treat | 12.390 12.356 12.106 | | 12.380 12.338 12.032
RR progression = 0 Treat all Test No test/No treat | 12.521 12.471 12.106 | | 12.479 12.425 12.032
RR progression = 0.5 Treat all Test No test/No treat | 12.349 12.320 12.106 | | 12.328 12.292 12.032
RR progression = 1 Treat all Test No test/No treat | 12.106 12.106 12.106 | | 12.032 12.032 12.032
Length of efficacy = 12 months Treat all Test No test/No treat | 12.119 12.117 12.106 | | 12.046 12.045 12.032
Length of efficacy = lifetime (base case) Treat all Test No test/No treat | 12.248 12.231 12.106 | | 12.206 12.182 12.032
Treatment complications = 0% Treat all Test No test/No treat | 12.273 12.253 12.106 | | 12.236 12.212 12.032
Treatment complications = 30% Treat all Test No test/No treat | 12.223 12.209 12.106 | | 12.175 12.158 12.032
Discount rate = 0% Treat all Test No test/No treat | 16.302 16.273 16.064 | | 16.206 16.172 15.919
Discount rate 5% Treat all Test No test/No treat | 10.401 10.389 10.297 | | 10.380 10.365 10.252
Complications = death Treat all Test No test/No treat | | 11.056 11.903 12.707 | 10.476 11.312 12.032
HYPOTHETICAL SCENARIOS
50% short-term decrease in utility Treat all Test No test/No treat | 12.177 12.195 12.106
20% lifetime decrease in utility Treat all Test No test/No treat | 11.900 12.055 12.106
RR for progression = 2 Treat all Test No test/No treat | 12.232 12.176 12.106 | | 12.188 12.223 12.032
RR for death = 2 Treat all Test No test/No treat | 12.219 12.216 12.106 | | 12.177 12.170 12.032

Table 10 Psychosocial, legal and ethical impacts of testing

Issues that have an impact | Demented individuals (Scenario A) | Individuals with mild cognitive impairment (Scenario B) | Asymptomatic individuals with an elevated risk individuals (Scenario C)
Autonomy | -May aid in end-of-life decisions | -May aid in end-of-life decisions | -May aid in reproduction decisions
Non-maleficence | -Little benefit as current treatment is benign | -Little benefit as current treatment is benign -May promote depression | -Little benefit as current treatment is benign -May promote depression
Beneficence | -False negative may lead to failure to provide useful treatment | -False negative may lead to failure to provide useful treatment | -No impact since treatment is not otherwise given
Justice | -May create a “PET” barrier for treatment | -May create a “PET” barrier for treatment | -No impact since treatment is not otherwise given
Liability | -False negative may result in failure to treat | -False negative may result in failure to treat | -Minor liability for false negative as treatment is not otherwise given -False positive may introduce liability from damage due to labeling effect
Employability | -No impact since patients almost never employed | -Minor impact as patients are rarely employed | -Major potential impact
Insurability | -No impact as course is poor regardless of AD diagnosis | -Major potential impact | -Major potential impact

(Bowen, Teri, Kukull, et al., 1997; Doraiswamy, Steffens, Pitchumoni, et al., 1998; Drickamer and Lachs, 1992; Erde, Nadal, and Scholl, 1988; Holroyd, Snustad, and Chalifoux, 1996; Morris, Storandt, Miller, et al., 2001)

Figure 2 S-ROC curve

For details about studies 1–10 please refer to Table 9

Text Box: Figure 2: S-ROC curve Text Box: For details about studies 1-10, please refer to Table 9

Figure 3 Two Way Sensitivity Analysis Mild Dementia

Text Box: Increasing Severity of Complication Text Box: 0 Base Case Text Box: 0

Figure 4 Two Way Sensitivity Analysis MCI

Text Box: Increasing Severity of Complication Text Box: Text Box: 0

Figure 5a Two Way Sensitivity Analysis Asymptomatic, Elevated Risk

Text Box: Increasing Severity of Complication Text Box: 0 Text Box: 0 Base Case

Figure 5b One Way Sensitivity Analysis

Asymptomatic, Elevated Risk - Treatment Efficacy set at RR=0.8

Text Box: Highest gain in QALYs = 14 days

Figure 5c One Way Sensitivity Analysis

Asymptomatic, Elevated Risk - Treatment Efficacy set at RR=0.5

Text Box: Highest gain in QALYs = 21 Days

Figure 5d One Way Sensitivity Analysis

Asymptomatic, Elevated Risk - Treatment Efficacy set at RR=0.3

Text Box: Highest gain in QALYs = 15 Days