# METHODOLOGY

The methods and procedures used to develop this report emphasized a comprehensive evaluation of the evidence regarding the operating characteristics of PET and an estimation of inputs required for the model. Because this effort was organized around a decision model, the section begins with the methodology employed for the construction of the model. This is followed by an explanation of our approach to the literature review regarding PET performance, including descriptions of the literature search, MeSH terms used, number and identity of the databases searched, and years included in the search. Finally, we describe the methodologies used to estimate other model inputs, including the probability of disease progression from year to year (transition probabilities) and the efficacy of treatment. By applying varying sensitivities and specificities of PET in our analysis, we have taken into consideration the effect of using any other neuroimaging modalities for diagnostic purposes.

## Methodology: Model Construction

### Purpose

The model was constructed to address the following question: For a patient with a given state of cognitive function, which strategy is more likely to provide better health outcomes? The specific cognitive states considered were 1) mild or moderate dementia, 2) mild cognitive impairment (MCI), and 3) asymptomatic with a first-degree relative with AD. These states correspond to the 3 key questions noted in the introduction and are denoted throughout this report as Scenario A, Scenario B, and Scenario C, respectively. The strategies examined were 1) no testing and no treatment, 2) testing with PET and treatment of patients with positive test results and 3) no testing but treatment of all patients. Since age is the dominant factor in the epidemiology of AD we have explicitly incorporated age into the structure of the model. The ages that we have considered for our analyses are 65 to 99 years. The rationale for the management strategies considered will be discussed in the “Results” section. All patients were assumed to have completed a standard work-up, as detailed in Appendix A.

### Methods

#### Structure of the Model

For the effectiveness analysis, we constructed a model with two major components. The first component was a 6-state decision model (Figure 1) that simulates the natural history of individuals who may have AD. The second component was an intervention model that represents possible screening/diagnosis and treatment strategies. The model was developed using DATA 3.5 software (Boston, MA: TreeAge Software, Inc). The structural and estimation assumptions made for the purpose of the model are stated in Table 1.

Figure 1 Basic state diagram of Markov model

The graphic is not available from the publisher at this time.

#### Natural History Component

The model follows a cohort of men and women from age 65 to 99 years. At the beginning of the simulation, all members of the cohort are assumed to be in one of the following states: asymptomatic, but at an elevated risk because of a family history of AD, MCI or mild or moderate dementia, definitions of these states are provided in Table 2, with details in Appendices B and C. Cycle lengths are one year.

Certain structural and estimation assumptions were made in the model (Table 1). An attempt was made to construct these assumptions to be unbiased for or against testing. When this was not possible, we have chosen assumptions that would favor testing.

For the natural history component of the model, patients can either remain in the same state or progress to a more severe state including severe dementia or death; regression to a less severe state is permitted structurally, but is assumed not to occur. In order to make the model more generic, its structure allows for future treatments that would actually reverse the progress of AD. For all analyses presented here, the probability of such backward transitions has been set to zero. [That is, for the present purposes we assume that any backward transitions observed are a result of measurement error and not a true improvement in state.] Patients who are asymptomatic but are at an elevated risk of developing dementia can either remain in the same state or progress to MCI. Patients who have MCI can either remain in that state or progress to mild dementia. Patients with mild dementia can either remain in the same state or progress to the moderate or severe state. Patients with moderate dementia can either remain in the same state or progress to the severe state. Patients with severe dementia can only remain in the same state or die. Progression rates for patients with mild, moderate or severe dementia depend only on observed symptoms and are not based on underlying AD. All patients are at risk from death from any causes. The states and allowed transitions of the natural history model are shown in Table 2, the model is in Appendix D. Note that patients are further characterized in the model with regard to their status as true positive (TP), true negative (TN), false positive (FP), or false negative (FN). This denotes the correspondence between the patients’ actual diagnosis (AD or no AD) and the diagnosis that would be assigned to them based on clinical and/or test results – the diagnosis that would be used for assigning a treatment. To be more explicit:

- TP = Diseased and treated as having AD
- FP = Not diseased and treated as having AD
- TN = Not diseased and treated as not having AD
- FN = Diseased and treated as not having AD.

#### Intervention Component

The intervention component of the decision model was constructed to allow a wide range of interventions to be considered including any test with a dichotomous outcome, any treatment that is unconditional or is conditional on either an immediate test result or future health event (i.e., progression to more severe symptoms). Treatments are modeled to have a risk of complications that can consist of any combination of short- and long-term disutility (decrement in quality of life), increase in rate of progression of symptoms, or increase in risk of death.

#### Measures of Effectiveness

We estimated effectiveness using several measures. First, we calculated life-years saved. This calculation allows comparison with other health interventions and with other (cost-effectiveness) analyses of PET scanning. We also calculated quality-adjusted life-years to account for the morbidity associated with each strategy. Weights for the quality adjustments were derived from the literature and applied to the natural history states and the states that would result from treatment and/or diagnosis using PET scanning (Neumann, Kuntz, Leon, et al., 1999). We estimated the percentage of true positives, false positives, true negatives, false negatives and correct diagnosis (true positives plus true negatives). [As noted above, these categorizations refer to the correspondence between a patient’s actual diagnosis (AD or no AD) and the diagnosis that would be assigned based on clinical and/or test results, i.e., the diagnosis that would be used for assigning a treatment. For example, a patient could be a true positive if he or she had AD, had a positive test and is treated, or if he or she is not tested and is treated nonetheless]. We also estimated severe-dementia-free life expectancy (SDFLE) for patients who have mild or moderate dementia and dementia-free life expectancy (DFLE) for patients who have MCI or who are asymptomatic but have an elevated risk of AD.

### Model Validation

The structure of the model was validated by asking various clinical experts to review its states, treatments, focus, and level of detail. The parameter inputs of the model were derived by the above literature review process and also presented to experts for additional review. The software implementation of the model was assessed 1) by noting that the relative impact of each of the factors in the one-way sensitivity analyses was in the anticipated direction and (2) by developing various extreme scenarios (e.g. test with 100% sensitivity and 100% specificity) and checking that the anticipated strategy was in fact preferred.

### Analysis

Base case analysis: For each scenario, we performed a base case analysis using the best available estimates for model inputs (Table 3).

One-way sensitivity analyses: We performed one-way sensitivity analysis by varying each model input over its plausible range (Table 3), keeping all other variables at their base case values.

Hypothetical treatment analyses: As it was evident from the onset that diagnostic tests can be particularly valuable when treatments are effective, but have significant adverse effects, we examined the impact of treatment complications on projected outcomes and preferred strategy. We considered several hypothetical treatments characterized by a variety of qualities. These include a treatment with long-term effects manifest as either a prolonged decrement in utility (50% reduction in utility for 1 year or 20% reduction in utility for a lifetime), an increase in rate of progression of disease (relative risk for progression of 2 for 1 year), or an increase in the mortality rate (relative risk for death of 5 for 1 year).

## Methodology: Literature Search

The literature search had two goals: 1) to identify all relevant clinical studies using 2-Fluro 2-deoxy D-glucose PET (FDG-PET) for diagnosis of AD and 2) to provide parameter estimates for the decision model. We utilized distinct procedures for identifying literature pertaining to these two goals. The methods for identifying and evaluating the FDG-PET literature are discussed in detail below. To identify parameter estimates that were needed for the decision model, specifically, estimates related to natural history of AD and the efficacy and adverse effects of treatment of AD, we focused on identifying existing systematic reviews, meta-analyses, or independent studies. In addition to referring to literature on previous decision models, we sought recommendations for high-quality studies from our local and consultant experts.

### Article identification

The comprehensive review of the literature was a multi-step process, identification of databases, abstraction of individual articles into the evidence tables, and the subsequent meta-analysis.

To identify articles pertaining to the characteristics of FDG-PE, we performed a comprehensive literature search. We worked through several iterations of the search strategies and excluded as many non-relevant articles as possible without jeopardizing the inclusion of relevant articles. The search strategy combined the concepts of “Alzheimer’s disease” and “positron emission tomography” and was limited to articles in English and on human subjects. In consideration of the advances in technology in recent years, we limited our search to articles published between the years 1995 and 2001. For the PET concept, we used the Medical Subject Heading (MeSH) term “ tomography, emission computed” and text word searches for “PET” and “FDG-PET”. To select articles with data on diagnostic performance of PET, we used the MeSH heading “sensitivity and specificity.” This strategy for MEDLINE elicited 162 articles.

Because this set of citations failed to include several articles known to us from a previous systematic review on this topic (Adams and Flynn, 1998), we then revised the search strategy by examining the indexing terms of the missed citations. We broadened our strategy to include the additional MeSH words “discriminant analysis”, “risk factors”, “case-control studies”, and “differential diagnosis” (Table 4). This search yielded 113 additional articles from MEDLINE for a total of 275 articles. We repeated the same process for CINAHL and HEALTHSTAR and identified an additional 7 citations.

Two reviewers – a methodological expert and a content expert – reviewed the abstracts of all the articles. At least one of the two reviewers selected 108 of the abstracts. Full text versions of these articles were then obtained. References from these articles were also examined, and pertinent ones acquired. The database finally had 320 articles.

### Selection Process

The criteria used to select an article for systematic review are detailed in Table 5.

Data Abstraction Process: Of the 320 citations reviewed, 42 were selected for a full-text review and abstraction (Appendix E). Two experts reviewed each of these 42 articles. Based on the inclusion criteria, 18 (43%) were included in the final review.

A quality score was also developed at this stage based on eight criteria that were considered relevant to the current analysis (Table 6). For each of the eight criteria, a score or zero of 1 was assigned: a score of 0 was assigned if the paper did not adequately meet the criterion or if the data were inadequate to determine the criterion, and a score of 1 was assigned if the paper met the criterion. The scores for all eight criteria were summed to give a final score for the study.

Two members of the project independently abstracted each study. They created a two-by-two table and extracted the key data that permitted calculation of sensitivity and specificity for use in analyzing the operating characteristics of the test. All the two-by-two table data were entered into a computer database, and data from the two members of each reviewing team were compared and reconciled. The entire process of literature search is summarized in Table 7.

The evidence table entries were created by one member of the team and were over-read by another member, and then revised. Fifteen articles included studies comparing AD patients with normal controls, and three studies compared AD and non-AD dementias. These 18 studies (43%) were further abstracted into evidence tables (Evidence Table 1).

### Meta-Analysis

Meta-analyses were performed to quantify the diagnostic performance and clinical impact of PET. The meta-analysis of PET diagnostic performance involved two technologies: (1) Summary Receiver Operating Characteristic (S-ROC) curve analysis and (2) Separately averaged sensitivity and specificity values across studies.

The S-ROC method assumes that the variability in the reported sensitivity and specificity values from different studies is due to different cutoff values being applied (Moses, Shapiro, and Littenberg, 1993) Each study provides a pair of sensitivity and specificity values to the analysis. It uses a regression method to fit a curve that best describes the data in the Receiver Operating Characteristic (ROC) space. We used the unweighted S-ROC method because it is considered less biased than the weighted regression method (Irwig, Macaskill, Glasziou, et al., 1995).

If multiple thresholds are available for individual diagnostic test studies, ROC curves can be constructed, and the areas under the curves can be estimated. The area under the curve provides an assessment of the overall accuracy of the test and allows comparisons with other tests.

However, the range of sensitivity and specificity values from studies in a meta-analysis of diagnostic tests is often limited, and extrapolation of the S-ROC analysis beyond the values of actual data is not reliable. When there is little variability in the test results – when studies appear to be operating at similar thresholds and report similar results – S-ROC analysis provides little additional information. In this case, separately averaged sensitivity and specificity values across studies will give similarly useful summary information.

We combined the sensitivity and specificity values of the tests across studies using a random effects model to estimate the average values. A random effects model incorporates both the within-study variation (sampling error) and between-study variation (true differences in discrimination) into the overall diagnostic performance estimates. The random effects model is conservative in the sense that it gives a wider confidence interval than the fixed effects model (which considers only within-study variability) when estimates are based on heterogeneous results.

When each result is combined separately, sensitivity and specificity tend to underestimate the true test sensitivity and specificity. They are nonetheless useful estimates of the average test performance and provide an indication of the approximate test operating point for most of the studies. Inspecting the location of the combined estimates and noting the distance of the combined estimates from the S-ROC curve can verify the appropriateness of this method. In our experience, the random effects-averaged sensitivity and specificity results are close to the unweighted S-ROC curve and well within the confidence intervals of each other. Average sensitivity and specificity results also serve as useful baseline test performance values for the decision and cost-effectiveness analysis (Lau, Balk, et al., 2001).

Statistical analyses using the S-ROC curve method and combining sensitivity and specificity using the random effects model were performed using the “Meta-Test” version 0.6. This computer program has been developed by Dr. Lau and is available to the public. We report 95 percent confidence intervals with all estimates.

## Methodology: Estimation of Inputs

In addition to estimating test sensitivity and specificity, our model required estimates of transition probabilities and treatment efficacy. Below we describe the steps taken to obtain these estimates, including the assumptions required.

### Transition Probabilities

It should be noted that our model requires age-specific probabilities of transitions between various states. However, based on the opinion of our experts in Alzheimer’s disease, no data set contains this information to the level of precision we require (including the otherwise excellent CERAD study). Accordingly, we have derived a method that combines various items of information available from the literature (e.g., overall population-based death rates by age but not state, transition probabilities by state but not age, etc.). Our approach involves first estimating transition probabilities for patients with AD, then estimating transition probabilities for those without AD.

#### Step 1 Estimate age-specific annual mortality rate of patients with AD

Age specific annual mortality rate of patients with AD were calculated using a US population life-table of annual mortality rates by age, an estimate of the prevalence of AD by age, and a risk ratio of death for patients with AD compared to patients without AD. We denote the age-specific mortality rate by µ_age_, the prevalence of AD as p (AD), the relative risk of death for patients with AD as RR_AD→D_, and the age-specific mortality rate for patients without AD as µ^no AD^_age_, we obtain the age-specific annual mortality rate for patients without AD by solving for µ^no AD^_age_. The age-specific annual mortality rate for patients with AD is

µ^AD^_age_ = (RR_AD→D_)(µ^no AD^_age_), where µ^no AD^_age_ = µ_age_/[(p (AD) (RR_AD→D_)+(1-p(AD))], derived from the relationship µ_age_ = (1-p(AD)) (µ^no AD^_age_) + (p(AD)) (RR_AD→D_) (µ^no AD^_age_)

This calculation assumes that the RR of death due to AD is the same for all ages.

#### Step 2 Estimate the age-specific mortality rates (i.e., transitions to death) for AD patients in the mild, moderate, and severe symptom categories

Using the above age-specific mortality rate for patients with AD, an estimate of the relative prevalence of symptoms for patients with dementia, the relative risk of death for patients with AD having moderate symptoms in comparison with patients having mild symptoms, and the relative risk of death for patients with AD having severe symptoms in comparison to those having mild symptoms, estimate the age- and symptom-specific mortality rates.

For a specific age group of patients with AD, we denote the overall mortality rate as µ^AD^_age_, the prevalence of mild, moderate, and severe symptoms as p_1_, p_2_ and p_3_ (p_1_+p_2_+p_3_=1), and the relative risk of moderate versus mild symptoms and the relative risk of severe versus mild symptoms as R_21_ and R_31_, respectively. Then, the age-specific annual mortality rate for patients with mild symptoms, µ_age_, solves

µ^AD^_age_ = (p1)(µ_age_) + (p_2_)(R_21_)(µ_age_) + (p_3_)(R_31_)(µ_age_)

The age-specific annual mortality rates for patients with moderate and severe symptoms are (R_21_)(µ_age_) and (R_31_)(µ_age_), respectively. This conclusion requires that we temporarily assume that all AD patients are symptomatic. For a person with clinically apparent AD, the distribution of symptom status is the same regardless of age. For patients with AD, the effect of symptom status on mortality is the same regardless of age. This temporary assumption is made in order to be consistent with the presentation of the CERAD data in the literature. This assumption will be dropped later.

#### Step 3 For patients with AD, estimate the probabilities of transitions to states other than death

Consider AD patients with mild symptoms. (The calculation method is the same for patients with moderate and severe symptoms). Denote the mortality rate by µ. Denote the CERAD-based overall (i.e., not age-specific) probabilities of transitions from mild to mild, moderate, severe, and death, and p_1_, p_2_, p_3_, and p_4_. Among the survivors, define X_11_= p_1_/(1-p_4_), X_21_ = p_2_/(1-p_4_), and X_31_ as p_3_/(1-p_4_). For any age group, the probability of death is p_4_*, and the probability of survival is 1-p_4_* (The distinction between p_4_ and p_4_* is that the latter has been estimated separately for each age group, in step 2 above). Obtain the transition probabilities as X_11_ = (1-p_4_*), X_21_ = (1-p_4_*), and X_31_ = (1-p_4_*), respectively. This requires the assumption that for those surviving to the end of the cycle, the RR of transitions to mild, moderate, and severe states is the same regardless of age.

We next turn to estimating the transition probabilities for symptomatic non-AD patients.

#### Step 4 For symptomatic patients without AD, set all of the above transition probabilities to equal those for patients with AD

This process is based on the assumption that once a patient becomes symptomatic, in the absence of treatment the course of disease is the same for AD and non-AD patients. (The model will subsequently assume that treatment is only effective for patients with AD).

We next turn to estimating the inputs of the model pertaining to patients without symptoms. These categories, in order of decreasing severity, are MCI, asymptomatic and at increased risk for AD, asymptomatic and not at increased risk for AD.

#### Step 5 Obtain the annual mortality rate for asymptomatic patients without AD

This mortality rate was obtained in step 1 above. We assume that this mortality rate applies to each of the subcategories of asymptomatic patients. Asymptomatic patients can only transition to MCI or death. (These transition probabilities will depend on whether the patient has AD). We are also assuming that the probability of a transition from a symptomatic state of mild, moderate, or severe dementia to a state such as asymptomatic or MCI is impossible. For additional details, please see the discussion of the overall model structure.

#### Step 6 Obtain the annual mortality rate for asymptomatic patients with AD

This mortality rate was obtained in step 1 above. An assumption used here is that AD does not have an impact on mortality until symptoms appear.

#### Step 7 Fill in the probabilities for transitions into the symptomatic states

Using the literature and expert judgment, we fill in the probabilities of transitions from asymptomatic to MCI for patients without AD, MCI to mild symptoms for patients without AD, asymptomatic to MCI for patients with AD, and MCI to mild symptoms for patients with AD.

For the MCI patients, we assumed that all patients, whether with AD or not, transition to symptoms at the same rate. This rate could thus be estimated from an epidemiological study of the general population of patients with MCI. The percentage of MCI patients having AD was estimated from a combination of the literature and expert judgment.

### Efficacy of treatment

Efficacy of treatment is reflected in the decision model by a transition probability multiplier K that influences the probability that a treated patient will move from state i to state j in one year. Specifically,

TP^T^_i,j_ = (K) (TP^NT^_i,j_)

where TP^NT^_i,j_ is the transition probability in the absence of treatment and state j is a more severe state of dementia than i. We assume that treatment does not decrease mortality directly; rather it indirectly decreases mortality by decreasing the likelihood of being in a more severe disability state with a corresponding high mortality rate. K cannot be estimated from most clinical trials as results are not typically presented in terms of state transitions over time. In the one trial report that presents results as “probability of survival with no clinically evident functional decline” (Mohs, Doody, Morris, et al., 2001), dementia worsening was not isolated from mortality. Since this latter study is otherwise representative of other RCTs, we estimate K from this study alone. We attempt to isolate the effect of treatment on progression to severe dementia by replacing missing mortality data with information from other sources.

Step 1: We assume that the survival curves for patients with no clinically evident functional decline will fit to the following declining exponential functions whether or not the patient has been treated:

S^NT^_t_ = exp(−(µ_1_ + µ_2_ + µ_3_) × t) without treatment (equation 1)

and

S^T^_t_ = exp(−((B × µ_1_)+ µ_2_ + µ_3_) × t) with treatment, (equation 2)

where

- µ_1_ is the hazard rate of transition from moderate dementia to severe dementia,
- µ_2_ is the hazard rate of transition from mild dementia to death,
- µ_3_ is the hazard rate of transition from moderate dementia to death, and
- B is a multiplier reflecting the impact of treatment on reducing the rate of transition from moderate dementia to severe dementia.

Step 2: We use equation 1 to estimate µ_1_ by replacing S^NT^_t_ and t with 0.5 and t’ where t’ is the time point in the clinical trial when 50% of the initial control population is either dead or have made the transition to severe dementia, replacing the mortality rates (µ_2_ and µ_3_) with values from a general dementia population of similar mean age to the clinical trial population, and solving algebraically. The validity of this estimate is based on the assumption that mortality in the control group of a trial population is similar to that of a general dementia population of similar mean age.

Step 3: We apply equation 2 to estimate B by using the mortality rates µ_1_, µ_2_, and µ_3_ obtained in the previous step, replacing S^T^_t_ and t with 0.5 and t”, where t” is the time point in the clinical trial when 50% of the initial treated population is either dead or has made the transition to severe dementia, and then solving algebraically.

Step 4: We convert the rates of transition from moderate to severe dementia [µ_1_ for untreated patients and (B) (µ_1_) for treated patients] to annual event probabilities by using the rate to probability conversion: p = 1 − exp (−((µ) (t))).

Step 5: We divide the probability of transition from moderate to severe dementia with treatment to the same probability without treatment. This ratio is K.

Based on our previous calculations, annual mortality rates for 75-year-old individuals with mild and moderate dementia are .026 and .065, respectively. From the study by Mohs, et al, t” (the time point in the clinical trial when 50% of the initial treated population either died or progressed to severe dementia) is approximately 48 weeks and t’ (the time point in the clinical trial when 50% of the initial control population either died or progressed to severe dementia) is approximately 30 weeks. This leads to an estimate for annual rate of transition from moderate dementia to severe dementia of .66 for treated patients ((−ln(.5)/(48/52)) − (.026+.065)) and 1.11 for untreated patients ((−ln(.5)/(30/52)) − (.026+.065)). The corresponding annual probabilities of progression to severe dementia are .48 and .67. The ratio, K, is 0.72

Table 1 Model assumptions

STRUCTURAL ASSUMPTIONS
1. Model has a one-year cycle i.e., no more than one model event can occur per year.; 2. Treatment is based on PET scan; positive results lead to treatment, negative results lead to non-treatment; 3. PET has an interpretable result.; 4. Every treated individual is affected by the treatment through a reduction in the probability of transition to more symptomatic states as opposed to a fraction of patients being affected by not progressing while the remainder is unaffected.; 5. Treatment effects begin at the start of treatment.; 6. Treatment effects are constant throughout the duration of treatment.; 7. Treatment benefits only those individuals with underlying AD.; 8. When treatment stops the effect of treatment stops.; 9. Treatment will not be initiated for severe dementia patients; if severe dementia develops during treatment, treatment will be discontinued.
ESTIMATION ASSUMPTIONS
1. PET sensitivity and specificity are estimated from data derived from all sites (i.e., results from academic sites can be extrapolated to community sites and vice versa).; 2. Once dementia develops, and after other causes of dementia have ruled out, progression to higher levels of disability occurs at the same rate for untreated AD patients as for non-AD patients, whether treated or not. The assumption is that dementia, no matter what the cause, is inexorably progressive, unless the patient has treated AD.; 3. Since Alzheimer’s disease is, by definition, a progressive disease, untreated individuals do not transition to less disabled states.; 4. Since the benefit of treatment is in stabilizing the existing cognitive state, treated individuals do not transition to less disabled states.; 5. Asymptomatic and MCI patients can only progress to the next more severe state in one year. [Note that this is assumption is not made for patients with dementia.]; 6. For purposes of calculating age-dependent mortality rates, the relative proportion of MCI, mild, moderate and severe dementia is assumed to be constant. [Note that in the model the distribution of dementia severities will change over time.]; 7. The mortality rate of MCI patients is the same as that for the general population.; 8. The probability of transition to MCI or to the next state of dementia does not depend on age.; 9. The risk ratio of death from an AD vs. a non-AD population is constant over age.; 10. For a given level of cognitive function, treatment does not affect mortality rate.; 11. For individuals with mild or moderate dementia or with mild cognitive impairment, treatment is continued for 18 months.; 12. For asymptomatic individuals at an elevated risk, treatment is continued until a state of severe dementia is reached.; 13. The benefits and adverse effects of treatment are constant over age.; 14. The only consequence of a treatment adverse event is that treatment is discontinued. [Note that this assumption has been made for the current treatment, the structure of the model allows all adverse events.]; 15. Utilities for a given level of cognition are unaffected by test results.

Table 2 Description of Markov model states

State | Definition | Allowable Transitions
Asymptomatic – elevated risk | Individual with one other first degree relative (parent, sibling, or child) with AD (Larson, Kukull, and Katzman, 1992) | Asymptomatic-at risk, MCI, mild dementia, moderate dementia, severe dementia, dead
MCI | CDR 0.5 | Asymptomatic – at risk^*^, MCI, mild, moderate, severe, dead
Mild | CDR 1 | Asymptomatic – at risk^*^, MCI^*^, mild, moderate, severe, dead
Moderate | CDR 2 | Asymptomatic – at risk^*^, MCI^*^, mild^*^, moderate, severe, dead
Severe | CDR 3 | Asymptomatic – at risk^*^, MCI^*^, mild^*^, moderate^*^, severe, dead
Dead | | Absorbing state

* Transitions that represent an improvement are allowed only for treatment.

Table 3 Input estimates

Input variable description | Baseline value | Range | Comment | Reference
Test operating characteristics
Sensitivity of PET Scanning | 0.86 | 0.74–0.92 | | Meta-analysis
Specificity of PET Scanning | 0.87 | 0.78–0.93 | | Meta-analysis
Utilities
Utility for asymptomatic state | 1 | 0.50–0.80 of base case utilities for all states | | McMahon et al 2000
Utility for MCI (irrespective of test results) | 0.73 | 0.50–0.80 of base case utilities for all states | | Neumann et al 2000
Utility for mild dementia (irrespective of test results | 0.69 | 0.50–0.80 of base case utilities for all states | | Neumann et al 2000
Utility for moderate dementia (irrespective of test results) | 0.53 | 0.50–0.80 of base case utilities for all states | | Neumann et al 2000
Utility for severe dementia | 0.38 | 0.50–0.80 of base case utilities for all states
Other estimates used in calculations
Mortality rates | Age specific | none | Based on life table estimates used for age specific mortality for asymptomatic, MCI and mild dementia patients (see section “Estimation of Inputs”) | National Health Statistics
Prevalence of dementia | Age specific | none | | Katzman 2001
Prevalence of AD in dementia | 0.56 | 0.50–0.85 | | Bachman et al 1992
Prevalence of AD in dementia | 0.56 | 0.50–0.85 | | McMahon et al 2000
Prevalence of AD in MCI | 0.80 | 0.70–1.00 | | Bowen et al 1997
Prevalence of AD in MCI | 0.80 | 0.70–1.00 | | Flicker 1991
Prevalence of AD in MCI | 0.80 | 0.70–1.00 | | Morris et al 1987
Prevalence of AD in MCI | 0.80 | 0.70–1.00 | | Petersen et al 2001
Prevalence of AD in MCI | 0.80 | 0.70–1.00 | | Wolf et al 1998
Lifetime risk of AD in first degree relatives | 0.50 | 0.30–0.70 | | Lautenschlager et al 1996
Lifetime risk of AD in first degree relatives | 0.50 | 0.30–0.70 | | Mohs et al 2001
Relative proportions of mild, moderate and severe AD | 0.36 mild AD | | | Cooper et al 1996
Relative proportions of mild, moderate and severe AD | 0.29 moderate | | | Cooper et al 1996
Relative proportions of mild, moderate and severe AD | AD | | | Cooper et al 1996
Relative proportions of mild, moderate and severe AD | 0.35 severe AD | | | Cooper et al 1996

(The estimates stated in the table are those for age 76 years. Calculations have been made for the entire range of ages - from 65 to 99 years.)

Table 4 Search Strategy

Database: MEDLINE <1966 to July Week 2 2001>
Set | Search | Results
1 | exp *alzheimer disease/di, ra | 2126
2 | exp tomography, emission-computed/ | 26569
3 | and/1–2 | 143
4 | fdg-pet.mp. | 1305
5 | 1 and 4 | 2
6 | or/3,5 | 143
7 | limit 6 to yr=1995–2001 | 83
8 | 6 not 7 | 60
9 | pet.tw. | 12266
10 | fdg-pet.tw. | 1305
11 | exp alzheimer disease/ | 24918
12 | sensitvity.mp. and specificity/ mp=title, | 1
13 | exp "sensitivity and specificity"/ | 105458
14 | or/2,4,9–10 | 30693
15 | or/1,11 | 24918
16 | and/14–15 | 982
17 | 13 and 16 | 76
18 | 6 or 17 | 202
19 | limit 18 to human | 199
20 | limit 19 to English language | 171
21 | discriminant analysis/ | 2905
22 | 21 and 16 | 13
23 | risk factors/ | 176939
24 | 23 and 16 | 29
25 | case control studies/ | 36560
26 | 25 and 16 | 47
27 | Diagnosis, differential/ | 216283
28 | 27 and 16 | 120
29 | or/22,24,26,28 | 195
30 | 29 not 18 | 133
31 | limit 30 to human | 133
32 | limit 31 to English language | 115

Table 5 Inclusion criteria used for studies included for estimating the operating characteristics of FDG-PET in AD

- Studies were in English language, reported primary data, and were published in a peer review journal (not abstracts).; - Studies included at least 12 human subjects (not animal studies) with the disease of interest.; - For studies of PET operating characteristics,; - Either clinical diagnosis or histopathological diagnosis was used as the reference standard.; - Data provided were sufficient to fill in a two-by-two table (PET result versus AD reference standard diagnosis). This criterion implies that patients with and without AD and patients with positive and negative PET results were included in the study.

Table 6 Quality score assigned to studies that were included for estimating the operating characteristics of FDG-PET in AD

- The study had a representative sample of patients with an appropriate spectrum of disease.; - The setting and selection of the population under investigation was clearly described.; - The scanner model or the type and the resolution of the scanner were mentioned.; - Standard criteria were used for test interpretation.; - The test reader and the person assigning reference standard diagnosis were blinded.; - The results were categorized by disease severity.; - The follow-up was complete (no verification bias).; - Histopathological or clinical confirmation was done on the basis of a long-term (>=one year) follow-up with standard criteria.

Table 7 Summary of literature search for the operating characteristics of PET in AD

| No. of articles
Medline preliminary search #1 | 162
Medline preliminary search #2 | 113
CINAHL and HealthSTAR searches | 7
Cross references | 38
Total no. of articles in database | 320
Abstracts selected for a full-text review by either reviewer | 113
Full text articles reviewed by both reviewers till date (includes cross-references) | 151
Articles included for data abstraction by both reviewers | 42
Reasons for exclusion of articles
(some articles had more than one reason for exclusion)
Article did not report primary data. | 55
Study included less than 12 human subjects | 12
Study did not use PET-FDG | 36
The diagnostic criteria used were not related to disease status (severity) | 3
Data was not adequate to fill in a two-by-two table | 45
Articles finally included in the evidence tables | 18