# INTRODUCTION

## Epidemiology

Each year approximately 350,000 individuals manifest Alzheimer’s disease (AD) (Brookmeyer, Gray, and Kawas, 1998). The incidence and prevalence of AD climb steadily after age 65 years so that 30–50% of individuals in the eighth to ninth decades have AD (Clark and Trojanowski, 2000).

AD is the most common etiology of dementia, representing approximately two-thirds of cases (Clark and Trojanowski, 2000; Knopman, DeKosky, Cummings, et al., 2001). Other dementias that can clinically present like AD include Lewy Body dementia, frontal lobe dementia, frontotemporal dementia, and vascular dementias. Since people with AD are also more likely to have co-morbidities such as diabetes and atherosclerosis, many people with AD pathology have dementia of mixed etiology.

AD is a complex genetic and environmental disorder (Roses, 1997). Among patients under the age of 65, the etiology of AD is dominated by autosomal dominant inherited mutations of the presenilin or amyloid precursor polypeptide genes (Selkoe, 1998) and polymorphisms of the apolipoprotein E gene (risk factor allele epsilon 4 or ApoE4) (Roses, 1997); together these genetic predispositions occur in 90% of the AD cases in younger individuals (Rubensztein and Easton, 1999). In late onset AD, genetic factors appear less prevalent with perhaps 60% of cases of AD in individuals aged over 65 years having ApoE4 (Rubensztein and Easton, 1999).

AD is a progressive neurodegenerative disease. Initial histological changes may be present in an asymptomatic individual; based on a study of asymptomatic autosomal dominant ApoE4 patients, such subclinical involvement may last for over 10 years (Knopman, DeKosky, Cummings, et al., 2001; Petersen, Stevens, Ganguli, et al., 2001). This is followed by mild cognitive impairment (MCI), which is distinguished from dementia by the absence of functional disability, or by mild dementia, which inexorably progresses through increasing levels of disability. The course of AD is highly variable. While 15% of patients with MCI progress in any given year (Petersen, Stevens, Ganguli, et al., 2001), prolonged plateau periods have been observed (Katzman, 2001). The total duration of clinical illness ranges from 5–25 years.

## Diagnosis

In the absence of any established biological marker for the diagnosis of AD or of disease activity, the current standard for diagnosis of AD is based on a clinical evaluation. The clinical evaluation recommended by the American Academy of Neurology (AAN) includes a complete history, physical and neuropsychiatric evaluation and screening laboratory testing (Knopman, DeKosky, Cummings, et al., 2001). They also recommend the use of anatomical neuroimaging in the initial evaluation of dementia. The diagnosis of AD is made when findings are consistent with AD (e.g., the patient has a cognitive disorder typical in type and course as AD and does not have a condition that may mimic AD in the early stages of disease, such as cerebrovascular disease, depression, metabolic disorder, sleep disorder, renal or liver disease, among others). It is not uncommon to have multiple diagnoses with a primary diagnosis of AD and with other causes of cognitive disorder also present in an individual patient (Clark and Trojanowski, 2000; Knopman, DeKosky, Cummings, et al., 2001), especially AD concomitant with vascular dementia. The prevalence of reversible dementia is 18%, but only 1% of cases are resolved entirely with treatment (Walstra, Teunisse, van Gool, et al., 1997).

For most patients with MCI and for some patients with early stages of dementia, diagnosis depends on the observation and documentation on repeat visits of clinical progression through follow-up visits over intervals of one-half to one year. For early or apparently stable cases, this period serves as a time to carry out initial evaluation, to establish neuropsychological baselines for comparison, to identify and treat any other acute or chronic medical condition likely to compromise cognitive or functional ability, and to observe clinically the patient’s actual course.

In addition to recommended examinations, other tests have been proposed for the evaluation of individuals who may have AD. Functional neuroimaging is one class of tests that may be useful for this purpose. Two approaches to functional neuroimaging include single-photon emission tomography (SPECT) and positron emission tomography (PET) with markers for cerebral blood flow or glucose metabolism. While neither of these modalities is currently recommended in the routine evaluation of dementia, they may have potential value because they can demonstrate in AD patients the expected anatomical pattern of bilateral hypometabolism in the temporal and parietal lobes (Hoffman, Welsh-Bohmer, Hanson, et al., 2000; Small, Ercoli, Silverman, et al., 2000). Notably, involvement of the frontal lobes, and some asymmetry in early cases is also observed. PET scans typical of AD can be differentiated clinically by visual inspection from scans suggestive of vascular etiology (asymmetric and focal abnormalities) and scans supportive of frontal lobe or lobar dementias (striking hypometabolism of frontal or temporal lobes with sparing of parietal lobes).

The potential for functional tests to identify individuals at the early stages of their disease is supported by studies of persons who are at increased genetic risk of AD because they bear one or more ApoE4 alleles. Even at ages much earlier than the average age of clinical onset such individuals have reduction of cerebral glucose metabolism corresponding to their grade of genetic risk (Bookheimer, Strojwas, Cohen, et al., 2000; Small, Ercoli, Silverman, et al., 2000). This area has the potential for further developments using the higher resolution of magnetic resonance imaging (MRI)spectroscopy, with the possible development of specific ligands for AD pathology, particularly amyloid plaques.

## Treatment

There is no known treatment to prevent or cure AD. Current therapies are aimed at symptomatic relief and at halting or slowing disease progression. Common treatment strategies include stroke risk reduction, antioxidant therapy (vitamin E), and use of cholinesterase inhibitors (AChE-I) even in prodromal or early stages (Doody, Stevens, Beck, et al., 2001). AChE-I therapy is aimed at correcting the central cholinergic deficit in persons with AD, This therapy has been shown to modestly delay the progression of disease in individuals with mild to moderate dementia (Mohs, Doody, Morris, et al., 2001), and it may also reduce the rate of institutionalization in patients with more severe dementia (Getsios, Caro, Caro, et al., 2001). Significant adverse events with currently recommended AChE-I therapy are uncommon (Mohs, Doody, Morris, et al., 2001). Approved AChE-I agents include donepezil (Aricept), rivastigmine (Exelon) and galantamine (Reminyl). Multicenter trials of AChE-I in MCI are already being conducted (Morris, Storandt, Miller, et al., 2001).

Future therapies are aimed at prevention, early treatment, and cure. Human trials of active immunization with β-Amyloid (Aβ) are underway. Aβ is a fibrillar 40–42 amino-acid peptide accumulating in the brains of AD patients and eliciting neuronal cell death (Gurwitz, 2001). Immunization with another Aβ-like peptide has been studied in mice, where reduced burden of the Aβ plaques were observed in the hippocampus and the cortical regions of the brain (Sigurdsson, Scholtzova, Mehta, et al., 2001). Other therapies based on the observation of Apolipoprotein E-4 (ApoE-4) as a genetic risk factor are under active development. These therapies may result in a significant slowing of the disease process of AD. If these therapies prove effective at early or even pre-clinical stages of AD, they will make the current standard diagnostic approach obsolete. The challenge for diagnosis will be not only to identify individuals with disease but also to rule out disease – especially if new therapies have common and significant adverse effects or are exceedingly expensive.

## Task Order- Evaluating the Role of PET in Patients who may have Alzheimer’s disease

It has been proposed that the tremendous burden of AD could be reduced by improved diagnosis. The Center for Medicare and Medicaid Services (CMS) has received a request for a national coverage decision on the use of Positron Emission Tomography (PET) for the diagnosis and management of Medicare beneficiaries with suspected AD and other dementias linked to old age. CMS referred the request to the Medicare Coverage Advisory Committee (MCAC) and asked the Agency of Healthcare Research and Quality (AHRQ) to review the existing scientific evidence with regard to the demonstrated and potential role of PET in reducing the burden of disease for individuals with possible AD. The Duke Evidence-based Practice Center has been commissioned by AHRQ to produce this report in support of the deliberations of the MCAC Diagnostic Imaging panel.

## Evaluation of PET in the Context of MCAC Guidelines

In determining the effectiveness of new medical products and services (e.g., laboratory tests, diagnostic procedures, treatments, each panel of the MCAC employs certain criteria and procedures to evaluate the adequacy of the evidence and magnitude of clinical benefit. The MCAC Executive Committee has issued general guidance to the panels in the form of suggestions about how to evaluate the adequacy of evidence and the magnitude of benefit (Medicare Coverage Advisory Committee, 2001). This report, meant to assist in the Diagnostic Imaging panel deliberations, incorporates the following recommendations issued by the Executive Committee.

First, it is necessary to determine whether the scientific evidence is adequate to draw conclusions about the effectiveness of the intervention in routine clinical use in the population of Medicare beneficiaries. Second, the size of health effect produced by the intervention must be evaluated. Evidence from well-designed studies must establish how the effectiveness of the new intervention compares to the effectiveness of established services and medical items.

When evidence is insufficient to draw conclusions about the effectiveness of an intervention, no attempt is made to classify the size of the possible effect. Instead, the reason for the determination of evidence is explained and an opinion is formed about the possibility of developing better evidence and the potential benefits of obtaining better information.

In order to evaluate diagnostic tests, the MCAC applies criteria similar to those used for other health interventions. Two basic questions are asked: (1) is the evidence adequate to determine whether the test provides more accurate diagnostic information? and (2) if the test improves accuracy, is the evidence adequate to determine how the improved accuracy affects health outcomes?

In this context, the task is to focus on the issue of the medical benefit of PET scanning, in addition to a standard evaluation (including a clinical examination and structural neuroimaging), for individuals who may have AD in comparison with other evaluation strategies that are currently covered by Medicare. As noted in the introduction, the comparator intervention is the clinical evaluation of individuals with cognitive impairment recommended in a guideline produced by the AAN (Knopman, DeKosky, Cummings, et al., 2001). This guideline is summarized in Appendix A.

The strongest support of a clinical benefit for a diagnostic test would be derived from direct evidence from a comprehensive randomized control trial. Such a trial would randomize patients to receive a conventional evaluation or an evaluation that includes the new test, and the primary study measure would be a clinical outcome that corresponds to the health burden of the disease. As detailed in this report, no study of PET in patients who may have AD has provided this level of evidence. Thus the evaluation of PET who may have AD must rely on indirect evidence.

While indirect evidence is less persuasive than direct evidence, it can nonetheless be sufficient for decision-making. Indirect evidence can be used to establish links in a logical or causal chain – in this case between PET use and diagnosis of AD and between diagnosis of AD and clinical outcome. The scientific evidence is evaluated to determine if use of PET leads to more accurate diagnosis of AD and if more accurate diagnosis of AD can (via appropriate treatment) lead to a clinically meaningful benefit.

To provide a fair evaluation of PET for patients who may have AD and to present an analysis that is useful to MCAC and CMS in current and future deliberations, we focused on the circumstance for which the evidence regarding treatment benefits is strongest – the presence of mild or moderate dementia. We link the evidence through the use of a Markov model. This model provides projections of a variety of important clinical outcomes. Sensitivity analysis is used to examine the robustness of these projections and to identify circumstances under which a new diagnostic test could be particularly attractive (e.g. a diagnostic test that is better than its comparator), or for a treatment that is associated with different levels of benefit and harm.) We extend this analysis to two additional scenarios for which important clinical evidence is either scanty or absent – testing for individuals with mild cognitive impairment, or testing asymptomatic individuals with a family history of AD in a first-degree relative. Here, we provide the CMS with a framework for future deliberations informed by new evidence about testing or treatment.

## Summary of Key Questions

The objectives described above were summarized in three key questions corresponding to the three clinical scenarios:

1. Scenario A: In patients with dementia, can PET be used to determine the type of dementia, thus facilitating early treatment of AD and perhaps other dementia subtypes?
2. Scenario B: For patients with MCI, could PET be used to identify a group of patients with a high probability of AD so that they could start early treatment?
3. Scenario C: Is the available evidence enough to justify the use of PET in a group of asymptomatic patients with an elevated risk in view of a family history of AD so that they could start early treatment?

We organized our responses for each key question/scenario into the following sub questions.

1. What are the possible clinical management options and corresponding expected outcomes for the scenario?
2. What is the diagnostic performance of PET in the scenario?
3. What are the benefits and adverse effects of treatment options that might be used in the scenario?
4. For a patient with a given state of cognitive function which strategy is most likely to provide better health outcomes?
5. What are the legal, ethical and psychosocial impacts of receiving a dementia diagnosis for individuals included in the scenario?