# Conclusions

Based on a comprehensive literature review, meta-analysis and decision analysis, we have the following four major conclusions regarding the use of PET in patients who may have AD:

1. For patients with dementia who have had a recommended clinical evaluation, treatment without further testing is superior to treating based on an additional test using PET. Since treatment for this clinical scenario has been shown to be moderately effective and relatively benign, the increase in true negatives (i.e. those who did not need the treatment) resulting from use of PET is overshadowed by the concomitant increase in false negatives (i.e. those who would benefit from the treatment, but for whom it would be withheld if they were not identified as positives).
2. If the evidence for treatment efficacy of AChE-I agents in patients with dementia can be extrapolated to patients with MCI, then empiric treatment of these patients would also be superior to treating based on PET. This is because the proportion of MCI patients with AD is comparable to – and may be higher than – the proportion of demented patients with AD. Even if survival is not improved, earlier treatment should improve the proportion of time a patient is alive with a lesser degree of impairment.
3. If the evidence for treatment efficacy of AChE-I agents in patients with dementia can be extrapolated to patients who are asymptomatic but have an elevated risk for AD, then empiric treatment of these patents would be superior to treating based on PET.
4. PET scanning could be of value if a new treatment were to be developed that was more effective but had a risk of one or more of a variety of highly negative consequences such as a reduction in quality of life, inducing progression of disease, or death.

There are two lines of speculation that suggest additional circumstances in which PET could be of value in patients who may have AD. The first line is that PET may identify a characteristic that predicts response to treatment beyond what can be predicted from clinical evaluation. However, we were unable to find trial or cohort studies to support this notion at this time.

The second line of speculation is that some patients, who should be treated with AChE-I agents but are not currently treated, would be treated if the physician were armed with an imaging study. While there is no support for this effect for PET in patients with dementia, there is support for the notion that a test – even a test of little or no incremental information value – can influence treatment behavior. However, it is quite possible that non-use of AChE-I agents would be unaffected by availability of PET if the decision to not treat with AChE-I medications is due, for example, to physician attitudes and beliefs (perhaps because they do not find the evidence supporting AChE-I medications compelling), financial considerations (out of pocket expenses for patients are onerous), or a combination (a perceived modest benefit is not worth the expense to the patient). In any case, if this value of testing is to be considered, it would be important to also consider the range of activities to improve clinician treatment practice.