# Markov model

Text Box: Appendix D: Markov model