# Clinical Dementia Rating (CDR)

Impairment
| None 0 | Questionable 0.5 | Mild 1 | Moderate 2 | Severe 3
Memory | No memory loss or slight inconstant forgetfulness | Consistent slight forgetfulness; partial recollection of events; “benign” forgetfulness | Moderate memory loss; more marked for recent events; defect interferes with everyday activities | Severe memory loss; only highly learned material retained; new material rapidly lost | Severe memory loss; only fragments remain
Orientation | Fully oriented | Fully oriented except for slight difficulty with time relationships | Moderate difficulty with time relationships; oriented for place at examination; may have geo-graphic disorientation elsewhere | Severe difficulty with time relationships; usually disoriented in time, often to place | Oriented to person only
Judgment & problem solving | Solves everyday problems well; judgment good in relation to past performance | Slight impairment in solving problems, similarities, differences | Moderate difficulty in handling problems, similarities, differences; social judgment usually maintained | Severely impaired in handling problems, similarities, differences; social judgment usually impaired | Unable to make judgments or solve problems
Community affairs | Independent function at usual level in job, shopping, business and financial affairs, volunteer and social groups | Slight impairment in these activities | Unable to function independently at these activities though may still be engaged in some; appears normal to casual inspection | No pretense of independent function outside home
Community affairs | Independent function at usual level in job, shopping, business and financial affairs, volunteer and social groups | Slight impairment in these activities | Unable to function independently at these activities though may still be engaged in some; appears normal to casual inspection | Appears well enough to be taken to functions outside a family home | Appears too ill to be taken to functions outside a family home
Home & hobbies | Life at home, hobbies, intellectual interests well maintained | Life at home, hobbies, intellectual interests slightly impaired | Mild but definite impairment of function at home; more difficult chores abandoned; more complicated hobbies and interests abandoned | Only simple chores preserved; very restricted interests, poorly sustained | No significant function in home
Personal care | Fully capable of self care | | Needs prompting | Requires assistance in dressing, hygiene, keeping of personal effects | Requires much help with personal care; frequent incontinence

Note: Score only as decline from previous usual level due to cognitive loss, not impairment due to other factors.

From Berg, L. Mild senile dementia of the Alzheimer type. In: Elizan, T.S., ed. Parkinson’s Disease, Alzheimer’s Disease, and the Aging Brain, Mt. Sinai Journal of Medicine, Vol. 55, pp. 87–96, 1988.