# Definitions

1. [underlined: Dementia –] The Diagnostic and Statistical Manual (DSM-IV) (McKhann, Drachman, Folstein, et al., 1984) of the American Psychiatric Association requires that for a diagnosis of dementia the diagnostic criteria of – “the development of multiple cognitive deficits that include memory impairment and at least one of the following: aphasia, apraxia, agnosia, or a disturbance in executive functioning”.
2. [underlined: Mild Cognitive Impairment]- Mild cognitive impairment refers to the clinical state of individuals who are memory impaired but are otherwise functioning well and do not meet clinical criteria for dementia (Petersen, Stevens, Ganguli, et al., 2001).
3. [underlined: Alzheimer’s disease] – In 1984, the Work Group convened by the National Institute of Neurological and Communicative Disorders and Stroke (NINCDS) and the Alzheimer’s Disease and Related Disorders Association (ADRDA) published criteria that standardized the diagnosis of AD (McKhann, Drachman, Folstein, et al., 1984) –
  In a demented person, probable AD is present when dementia is characterized by gradual onset and progression and when other systemic or brain disorders that potentially could cause dementia are absent. Possible AD is diagnosed if there are variations in the presentation or course of dementia or when other potentially dementing disorder (e.g., stroke) is present but is believed not to be responsible for dementia. The term definite AD is reserved for cases of clinically diagnosed AD in which there is histopathological confirmation by cerebral biopsy or autopsy.
4. [underlined: Staging Instruments for Alzheimer’s disease] - Several clinical rating scales can be used to provide a global measure of the severity of dementia. They are sensitive indicators of cognitive change. The Clinical Dementia Rating is a five point ordinal scale, assesses cognitive ability by structured informant interview and patient testing in six domains with individual descriptors for each level of severity in each domain. The Global Deterioration Scale (GDS) and the CAMDEX are other instruments that can also be used.

We have used the CDR scale, since this is the scale that the CERAD has utilized to grade its patients, and since that is the data set that we have used in some parts of our analysis. This scale designates 1 as mild dementia, 2 as moderate and 3 as severe dementia. (Appendix C)

Mild dementia (CDR stage 1) – Memory impairment in these individuals interferes with their daily activities. There are growing difficulties handling complex problems and managing independence in household responsibilities and daily activities (Scinto and Daffner, 2000).

Moderate dementia (CDR stage 2) – These individuals exhibit significant memory loss, frequent disorientation, impairment of social judgment, and an increasing need for supervision in their daily living activities (Scinto and Daffner, 2000).

Severe dementia (CDR stage 3 and beyond) – Patients are totally dependent on others for personal care and everyday problem solving (Scinto and Daffner, 2000; McKhann, Drachman, Folstein, et al., 1984; Petersen, Stevens, Ganguli, et al., 2001).