# American Academy of Neurology Guidelines

Practice Parameter: Diagnosis of dementia (an evidence-based review)

Report of the Quality Standards Subcommittee of the American Academy of Neurology

The recommendations made are –

1. The DSM-III-R definition of dementia is reliable and should be used (Guideline)
2. The National Institute of Neurologic, Communicative Disorders and Stroke-ADD and Related Disorders Association (NINCDS-ADRDA) or the Diagnostic and Statistical manual, 3rd edition, revised (DSM-IIIR) diagnostic criteria for AD and clinical criteria for Creutzfeldt-Jacob disease (CJD) have sufficient reliability and validity and should be used (Guideline). Diagnostic criteria for vascular dementia, dementia with Lewy bodies, and frontotemporal dementia may be of use in clinical practice (Option) but have imperfect reliability and validity.
3. Structural neuroimaging with a non-contrast CT or MR scan in the initial evaluation of dementia is appropriate. Because of insufficient data on validity, no other imaging procedure is recommended (Guideline). There are no currently genetic markers recommended for routine diagnostic purposes (Guideline). The CSF 14-3-3 protein is useful for confirming or rejecting the diagnosis of CJD (Guideline).
4. Screening for depression, B12 deficiency, and hypothyroidism should be performed (Guideline). Screening for syphilis in patients with dementia is not justified unless clinical justification for neurosyphilis is present (Guideline).

Knopman, DeKosky, Cummings, et al., 2001)