# Abbreviations Used in the Text

AAN: American Academy of Neurology
Aβ: Beta-amyloid
AChE-I: Cholinesterase inhibitor
AD: Alzheimer’s disease
AHRQ: Agency for Healthcare Research and Quality
ApoE4: Apolipoprotein E-4
cc: Cubic centimeter(s)
CDR: Clinical Dementia Rating
CI: Confidence interval
cm: Centimeter(s)
CMS: Centers for Medicare and Medicaid Services
DFLE: Dementia free life expectancy
DSM: Diagnostic and Statistical Manual of the American Psychiatric Association
FDG: 2-Fluro 2-deoxy D-glucose
g: Gram(s)
L-DOPA: Levo dopa
LE: Life expectancy
MCI`: Mild cognitive impairment
MCAC: Medicare Coverage Advisory Committee
MeSH: Medical Subject Heading
µg: Microgram(s)
mg: Milligram
ml: Milliliter(s)
MMSE: Mini-mental State Examination
MRI: Magnetic Resonance Imaging
mU: Milliunit(s)
ng: Nanogram(s)
NINCDS-ADRDA: National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Association
NR: not reported
NSAID: Non-steroidal anti-inflammatory drug
OR: Odds ratio
PD: Parkinson’s disease
PET: Positron emission tomography
QOL: Quality of life
QALY: Quality adjusted life expectancy
RCT: Randomized controlled trials
ROC: Receiver operating characteristic
RR: Relative risk
SDFLE: Severe dementia -free life expectancy
SPECT: Single photon emission tomography
SROC: Summary receiver operating characteristic
TP: Transition probability
vs.: Versus
%: Percent