# Evidence Table

Evidence Table 1

Abbreviations Used in the Evidence Tables
AD: Alzheimer’s disease
DLB: Dementia with Lewy bodies
FDG: 2-Fluro 2-deoxy D-glucose
FWHM: Full-width at half maximum
MBq: milli Bequerel
MCI: Mild Cognitive Impairment
MID: Multi-infarct dementia
MIX: Mixture of multi-infarct dementia and AD
MMSE: Mini-mental State Examination
NINCDS-ADRDA: National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer’s Disease and Related Disorders Association
No.: Number
NR: Not recorded
VD: Vascular dementia
vs.: versus
%: Percent