# SUMMARY

## Objective

To assess the benefits for Positron Emission Tomography (PET) scanning in patients with dementia, in patients with mild cognitive impairment and in asymptomatic patients with a family history of Alzheimer’s disease (AD), subsequent to the standard evaluation as described in the American Academy of Neurology (AAN) guidelines. The assessment was done by reviewing the scientific evidence regarding the performance of PET, the natural history of AD, and the treatment efficacy and adverse effects of PET, and by creating a decision model linking testing with treatment and outcome. We have used PET as a prototype for a neuroimaging test; however, the model can be applied to a broad range of neuroimaging modalities and treatments.

## Search Strategy

We utilized distinct procedures for identifying literature on the natural history of AD and the effectiveness of treatment for AD versus studies of diagnostic performance of PET using 2-Fluro 2-deoxy D-glucose (FDG-PET). We searched the MEDLINE, CINAHL and the HealthSTAR databases from January 1996 to January 2001 for studies describing the operating characteristics of PET. For articles on the natural history of AD and treatment of AD, we focused on identifying the best quality articles best qualified to inform the decision model’s parameter requirements.

## Selection Criteria

We identified 15 articles published in peer- reviewed journals and containing original data on more than twelve human subjects relevant to the efficacy of PET in the diagnosis of AD. The reference standard used was either histopathology or clinical diagnosis.

## Data Collection and Analysis

Information from these selected studies was used to construct evidence tables. We analyzed the studies by constructing a summary receiver operating characteristic (SROC) curve. Test performance, natural history and quality of life studies were used to provide baseline and range estimates for an integrative model. This integrative model was a Markov decision model constructed using DATA 3.5 software (Boston, MA: TreeAge Software, Inc). The decision model was evaluated with regard to individuals presenting with

- dementia (Scenario A)
- mild cognitive impairment (MCI) (Scenario B), and
- no symptoms, but with a first-degree relative with AD (Scenario C).

In addition to a base-case analysis geared to the “typical” individual in the scenario, we performed extensive sensitivity analyses to evaluate the robustness of the baseline conclusions as well as to allow an evaluation of hypothetical scenarios not supported by the current evidence. That is, we recognized that in the future more efficacious treatments might become available and that these treatments might or might not have greater side effects than the current treatments. Our sensitivity analyses illustrate the impact of such treatments on the results.

## Main Results

For patients with mild or moderate dementia, three strategies were considered: (1) to treat all patients with a diagnosis of AD after a standard work-up with anticholinesterases (AChE-I) – “Treat All”, (2) treat only if PET positive – “Test”, and (3) not to test or treat – “No Test/No Treat”. Physical outcomes were measured by life expectancy, quality-adjusted life expectancy, and severe- dementia-free life expectancy. The pooled sensitivity estimate for PET (95% confidence interval) was determined to be 88% (79% to 94%), and a pooled specificity estimate of 87% (77% to 93%) for distinguishing normal healthy controls from patients with AD.

For the baseline case analysis in patients with dementia (Scenario A), the “Treat All” strategy is preferred over the other two in terms of quality-adjusted life years, life expectancy or severe-dementia-free life expectancy. The absolute difference between the strategies is small, but is robust in sensitivity analyses. This implies that although costs were not considered in this assessment, the direction of the conclusions would not change if costs were to be included. The “Test” strategy is preferred only in terms of the measure “percentage correct diagnosis”. When hypothetical treatments are considered, “Test” becomes the more attractive strategy as complications becomes more severe. But if efficacy is simultaneously increased with dangerous treatment – as it logically should be in order to be worth considering – “Test” becomes less attractive.

For patients with MCI (Scenario B), the evidence for treatment efficacy is assumed to be the same as that for dementia patients since the results of the analysis are virtually the same as for patients with dementia.

For asymptomatic individuals with an elevated risk (Scenario C), the “Treat All” strategy is preferred in the base case, as with the symptomatic scenarios. This approach presumes that treatment is effective in this population. Testing could become preferred for a hypothetical treatment that is highly effective but associated with a risk of severe decrement in quality of life.