# Bibliography

Adams E, Flynn K. Positron emission toography: A systematic review update of FDGPET as a diagnostic test in cancer and Alzheimer's disease. Technology Assessment Report No. 10. Health Services Research and Development Service, Department of Veterans Affairs. 1998.
Albert MS, Lafleche G. Neuroimaging in Alzheimer's disease. Psychiatr Clin North Am. 1991;14(2):443-459. [pmid: 2062727].
Alexander GE, Furey ML, Grady CL, et al. Association of premorbid intellectual function with cerebral metabolism in Alzheimer's disease: implications for the cognitive reserve hypothesis. Am J Psychiatry. 1997;154(2):165-172. [pmid: 9016263].
Almkvist O, Winblad B. Early diagnosis of Alzheimer dementia based on clinical and biological factors. Eur Arch Psychiatry Clin Neurosci. Suppl 3. 1999;249:3-9. [pmid: 10654093].
Anonymous. Nuclear medicine targets early signs. Asrt Scanner. 1996;28(11):8.
Anonymous. Use of positron emission tomography in diagnosing Alzheimer's disease. J Neurosci Nurs. 1996;28(4):275.
Asada T, Motonaga T, Yamagata Z, et al. Associations between retrospectively recalled napping behavior and later development of Alzheimer's disease: association with APOE genotypes. Sleep. 2000;23(5):629-634. [pmid: 10947030].
Awad IA, Johnson PC, Spetzler RF, et al. Incidental subcortical lesions identified on magnetic resonance imaging in the elderly. II. Postmortem pathological correlations. Stroke. 1986;17(6):1090-1097. [pmid: 3810706].
Azari NP, Pettigrew KD, Pietrini P, et al. Detection of an Alzheimer disease pattern of cerebral metabolism in Down syndrome. Dementia. 1994;5(2):69-78. [pmid: 8038869].
Azari NP, Pettigrew KD, Schapiro MB, et al. Early detection of Alzheimer's disease: a statistical approach using positron emission tomographic data. J Cereb Blood Flow Metab. 1993;13(3):438-447. [pmid: 8478402].
Bachman DL, Wolf PA, Linn R, et al. Prevalence of dementia and probable senile dementia of the Alzheimer type in the Framingham Study. Neurology. 1992;42(1):115-119. [pmid: 1734291].
Bacskai BJ, Kajdasz ST, Christie RH, et al. Imaging of amyloid-beta deposits in brains of living mice permits direct observation of clearance of plaques with immunotherapy. Nature Med. 2001;7(3):369-372. [pmid: 11231639].
Baldwin RC. Localized cerebral atrophy: an important cause of non-Alzheimer's dementia. Br J Hosp Med. 1993;50(6):309-314. [pmid: 8242214].
Bard F, Cannon C, Barbour R, et al. Peripherally administered antibodies against amyloid beta-peptide enter the central nervous system and reduce pathology in a mouse model of Alzheimer disease. Nature Med. 2000;6(8):916-919. [pmid: 10932230].
Barra V, Boire JV. A general framework for the fusion of anatomical and functional medical images. Neuroimage. 2001;13(3):410-424. [pmid: 11170807].
Benson DF, Kuhl DE, Hawkins RA, et al. The fluorodeoxyglucose 18F scan in Alzheimer's disease and multi-infarct dementia. Arch Neurol. 1983;40(12):711-714. [pmid: 6605139].
Berg L. Mild senile dementia of the Alzheimer type. Mt Sinai J Med. 1988;55:87-96. [pmid: 3279307].
Bergman H, Chertkow H, Wolfson C, et al. HM-PAO (CERETEC) SPECT brain scanning in the diagnosis of Alzheimer's disease. J Am Geriatr Soc. 1997;45(1):15-20. [pmid: 8994482].
Besson JA, Crawford JR, Parker DM, et al. Multimodal imaging in Alzheimer's disease. The relationship between MRI, SPECT, cognitive and pathological changes. Br J Psychiatry. 1990;157:216-220. [pmid: 2224371].
Besson JA, Crawford JR, Parker DM, et al. Neuroimaging, cognitive, and pathological changes in dementia of the Alzheimer type (DAT). Psychiatry Res. 1989;29(3):447-448. [pmid: 2608816].
Bickel U, Lee VM, Trojanowski JQ, et al. Development and in vitro characterization of a cationized monoclonal antibody against beta A4 protein: a potential probe for Alzheimer's disease. Bioconjug Chem. 1994;5(2):119-125. [pmid: 8031874].
Birks J, Flicker L. Selegiline for Alzheimer's disease (Cochrane Review). The Cochrane Library, Issue 3, 2001. Oxford. Update Software.
Blacker D, Albert MS, Bassett SS, et al. Reliability and validity of NINCDS-ADRDA criteria for Alzheimer's disease. The National Institute of Mental Health Genetics Initiative. Archives of Neurology. 1994;51(12):1198-1204. [pmid: 7986174].
Bonte FJ. Brain blood flow SPECT: posterior flow deficits in young patients with depression. Clin Nucl Med. 1999;24(9):696-697. [pmid: 10478750].
Bonte FJ, Weiner MF, Bigio EH, et al. Brain blood flow in the dementias: SPECT with histopathologic correlation in 54 patients. Radiology. 1997;202(3):793-797. [pmid: 9051035].
Bookheimer SY, Strojwas MH, Cohen MS, et al. Patterns of brain activation in people at risk for Alzheimer's disease. N Engl J Med. 2000;343(7):450-456. [pmid: 10944562].
Bottino CM, Almeida OP. Can neuroimaging techniques identify individuals at risk of developing Alzheimer's disease. Int Psychogeriatr. 1997;9(4):389-403. [pmid: 9549589].
Bowen J, Teri L, Kukull W, et al. Progression to dementia in patients with isolated memory loss. Lancet. 1997;349(9054):763-765. [pmid: 9074575].
Breitner JC. Clinical genetics and genetic counseling in Alzheimer disease. Ann Intern Med. 1991;115(8):601-606. [pmid: 1892331].
Brookmeyer R, Gray S, Kawas C. Projections of Alzheimer's disease in the United States and the public health impact of delaying disease onset. Am J Publ Health. 1998;88(9):1337-1342.
Buchpiguel CA, Mathias SC, Itaya LY, et al. Brain SPECT in dementia. A clinical-scintigraphic correlation. Arq Neuropsiquiatr. 1996;54(3):375-383. [pmid: 9109979].
Buchsbaum MS, Kesslak JP, Lynch G, et al. Temporal and hippocampal metabolic rate during an olfactory memory task assessed by positron emission tomography in patients with dementia of the Alzheimer type and controls. Preliminary studies. Arch Gen Psychiatry. 1991;48(9):840-847. [pmid: 1929775].
Budinger TF. Future research in Alzheimer's disease using imaging techniques. Neurobiol Aging. Suppl 2. 1994;15:S41-S48. [pmid: 7700458].
Burdette JH, Minoshima S, Vander Borght T, et al. Alzheimer disease: improved visual interpretation of PET images by using three-dimensional stereotaxic surface projections. Radiology. 1996;198(3):837-843. [pmid: 8628880].
Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease - results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237-244. [pmid: 10325453].
Butler RE, Costa DC, Ell PJ, et al. Diagnosing Alzheimer's disease. BMJ. 1992;304(6826):574-575. [pmid: 1489376].
Charpentier P, Lavenu I, Defebvre L, et al. Alzheimer's disease and frontotemporal dementia are differentiated by discriminant analysis applied to (99m)Tc HmPAO SPECT data. J Neurol Neurosurg Psychiatry. 2000;69(5):661-663. [pmid: 11032624].
Chase TN, Foster NL, Fedio P, et al. Regional cortical dysfunction in Alzheimer's disease as determined by positron emission tomography. Ann Neurol. Suppl. 1984;15:S170-S174. [pmid: 6611118].
Clark CM, Trojanowski JQ. Neurodegenerative dementias. New York. McGraw-Hill. 2000.
Claus JJ, Dubois EA, Booij J, et al. Demonstration of a reduction in muscarinic receptor binding in early Alzheimer's disease using iodine-123 dexetimide single-photon emission tomography. Eur J Nucl Med. 1997;24(6):602-608. [pmid: 9169565].
Claus JJ, Dubois EA, Booij J, et al. Demonstration of a reduction in muscarinic receptor binding in early Alzheimer's disease using iodine-123 dexetimide single-photon emission tomography. Eur J Nucl Med. 1997;24(6):602-608. [pmid: 9169565].
Claus JJ, van Gool WA, Feldman H, et al. SPECT in AD. Neurology. 1997;48(4):1139-1140. [pmid: 9109925].
Claus JJ, van Harskamp F, Breteler MM, et al. The diagnostic value of SPECT with Tc 99m HMPAO in Alzheimer's disease: a population-based study. Neurology. 1994;44(3 Pt 1):454-461. [pmid: 8145915].
Claus JJ, van Harskamp F, Breteler MM, et al. Assessment of cerebral perfusion with single-photon emission tomography in normal subjects and in patients with Alzheimer's disease: effects of region of interest selection. Eur J Nucl Med. 1994;21(10):1044-1051. [pmid: 7828613].
Cohen MB, Graham LS, Lake R, et al. Diagnosis of Alzheimer's disease and multiple infarct dementia by tomographic imaging of iodine-123 IMP. J Nucl Med. 1986;27(6):769-774. [pmid: 3486961].
Cohen RM, Andreason PJ, Sunderland T. The ratio of mesial to neocortical temporal lobe blood flow as a predictor of dementia. J Am Geriatr Soc. 1997;45(3):329-333. [pmid: 9063279].
Cooper B, Bickel H, Schaufele M. Early development and progression of dementing illness in the elderly: a general-practice based study. Psychologic Med. 1996;26(2):411-419.
Corder EH, Jelic V, Basun H, et al. No difference in cerebral glucose metabolism in patients with Alzheimer disease and differing apolipoprotein E genotypes. Arch Neurol. 1997;54(3):273-277. [pmid: 9074396].
Cordery RJ, Tyrrell PJ, Lantos PL, et al. Dementia with Lewy bodies studied with positron emission tomography. Arch Neurol. 2001;58(3):505-508. [pmid: 11255457].
Curran SM, Murray CM, Van Beck M, et al. A single photon emission computerized tomography study of regional brain function in elderly patients with major depression and with Alzheimer-type dementia. Br J Psychiatry. 1993;163:155-165. [pmid: 8075905].
Cutler NR. Cerebral metabolism as measured with positron emission tomography (PET) and [18F] 2-deoxy-D-glucose: healthy aging, Alzheimer's disease and Down syndrome. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(3–5):309-321. [pmid: 2948218].
Cutler NR, Haxby JV, Duara R, et al. Clinical history, brain metabolism, and neuropsychological function in Alzheimer's disease. Ann Neurol. 1985;18(3):298-309. [pmid: 3876805].
Cutts DA, Maguire RP, Stedman JD, et al. A comparative study in Alzheimer's and normal brains of trace element distribution using PIXE and INA analyses and glucose metabolism by positron emission tomography. Biol Trace Elem Res. 1999;71–71:541-549.
Davis PC, Mirra SS, Alazraki N. The brain in older persons with and without dementia: findings on MR, PET, and SPECT images. Am J Roentgenol. 1994;162(6):1267-1278. [pmid: 8191980].
de Leon MJ, Ferris SH, George AE, et al. Computed tomography and positron emission transaxial tomography evaluations of normal aging and Alzheimer's disease. J Cereb Blood Flow Metab. 1983;3(3):391-394. [pmid: 6603463].
de Leon MJ, George AE, Ferris SH, et al. Regional correlation of PET and CT in senile dementia of the Alzheimer type. Am J Neuroradiol. 1983;4(3):553-556. [pmid: 6410795].
de Leon MJ, George AE, Marcus DL, et al. Positron emission tomography with the deoxyglucose technique and the diagnosis of Alzheimer's disease. Neurobiol Aging. 1988;9(1):88-90. [pmid: 3260012].
De Oliveira SA, Castro MJ, Bittencourt PR. Slowly progressive aphasia followed by Alzheimer's dementia: a case report. Arq Neuropsiquiatr. 1989;47(1):72-75. [pmid: 2788403].
Defebvre LJ, Leduc V, Duhamel A, et al. Technetium HMPAO SPECT study in dementia with Lewy bodies, Alzheimer's disease and idiopathic Parkinson's disease. J Nucl Med. 1999;40(6):956-962. [pmid: 10452310].
Deisenhammer E, Reisecker F, Leblhuber F, et al. Single photon emission computed tomography (SPECT) and X-ray CT in patients with dementia. Psychiatry Res. 1989;29(3):443-445. [pmid: 2608815].
DeKosky ST, Shih WJ, Schmitt FA, et al. Assessing utility of single photon emission computed tomography (SPECT) scan in Alzheimer disease: correlation with cognitive severity. Alzheimer Dis Assoc Disord. 1990;4(1):14-23. [pmid: 2317335].
Derouesne C, Rancurel G, Le Poncin Lafitte M, et al. Variability of cerebral blood flow defects in Alzheimer's disease on 123iodo-isopropyl-amphetamine and single photon emission tomography. Lancet. 1985;1(8440):1282. [pmid: 2860485].
Dewan MJ, Gupta S. Toward a definite diagnosis of Alzheimer's disease. Compr Psychiatry. 1992;33(4):282-290. [pmid: 1643871].
Dierckx RA, Appel B, Saerens J, et al. Tc-99m HMPAO brain SPECT in dementia due to transitory obstructive hydrocephalus. Clin Nucl Med. 1993;18(3):245-246. [pmid: 8462221].
Donnemiller E, Heilmann J, Wenning GK, et al. Brain perfusion scintigraphy with 99mTc-HMPAO or 99mTc-ECD and 123I-beta-CIT single-photon emission tomography in dementia of the Alzheimer-type and diffuse Lewy body disease. Eur J Nucl Med. 1997;24(3):320-325. [pmid: 9143472].
Doody RS, Stevens JC, Beck C, et al. Practice parameter: management of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1154-1166. [pmid: 11342679].
Doraiswamy PM, Steffens DC, Pitchumoni S, et al. Early recognition of Alzheimer's disease: what is consensual? What is controversial? What is practical. J Clin Psychiatry. Suppl 13. 1998;59:6-18. [pmid: 9771825].
Draper B, MacCuspie-Moore C, Brodaty H. Suicidal ideation and the 'wish to die' in dementia patients: the role of depression. Age & Ageing. 1998;27(4):503-507. [pmid: 9884008].
Drickamer MA, Lachs MS. Should patients with Alzheimer's disease be told their diagnosis. N Engl J Med. 1992;326(14):947-951. [pmid: 1542346].
Duara R, Barker W, Loewenstein D, et al. Sensitivity and specificity of positron emission tomography and magnetic resonance imaging studies in Alzheimer's disease and multi-infarct dementia. Eur Neurol. Suppl 3. 1989;29:9-15. [pmid: 2612532].
Duara R, Barker W, Luis CA. Frontotemporal dementia and Alzheimer's disease: differential diagnosis. Dement Geriatr Cogn Disord. Suppl 1. 1999;10:37-42. [pmid: 10436338].
Duara R, Galasko D, Schellenberg G. Unlocking the mysteries of Alzheimer's disease. Patient Care. 1996;30(18):44-46. 51. 53. 57–8 passim.
Duara R, Grady C, Haxby J, et al. Positron emission tomography in Alzheimer's disease. Neurology. 1986;36(7):879-887. [pmid: 3487046].
Duara R, Lopez-Alberola RF, Barker WW, et al. A comparison of familial and sporadic Alzheimer's disease. Neurology. 1993;43(7):1377-1384. [pmid: 8327141].
Eagger S, Syed GM, Burns A, et al. Morphologic (CT) and functional (rCBF-SPECT) correlates in Alzheimer's disease. Nucl Med Commun. 1992;13(9):644-647. [pmid: 1448236].
Ebmeier KP, Besson JA, Crawford JR, et al. Nuclear magnetic resonance imaging and single photon emission tomography with radio-iodine labeled compounds in the diagnosis of dementia. Acta Psychiatr Scand. 1987;75(5):549-556. [pmid: 3496733].
Ebmeier KP, Glabus MF, Prentice N, et al. A voxel-based analysis of cerebral perfusion in dementia and depression of old age. Neuroimage. 1998;7(3):199-208. [pmid: 9597661].
El Fakhri G, Moore SC, Maksud P, et al. Absolute activity quantitation in simultaneous 123I/99mTc brain SPECT. J Nucl Med. 2001;42(2):300-308. [pmid: 11216530].
Emery VO, Oxman TE. Update on the dementia spectrum of depression. Am J Psychiatry. 1992;149(3):305-317. [pmid: 1536267].
Erde EL, Nadal EC, Scholl TO. On truth telling and the diagnosis of Alzheimer's disease. J Family Pract. 1988;26(4):401-406.
Faulstich ME. Brain imaging in dementia of the Alzheimer type. Int J Neurosci. 1991;57(1–2):39-49. [pmid: 1938155].
Fazekas F, Alavi A, Chawluk JB, et al. Comparison of CT, MR, and PET in Alzheimer's dementia and normal aging. J Nucl Med. 1989;30(10):1607-1615. [pmid: 2795200].
Flicker C, Ferris SH, Reisberg B. Mild cognitive impairment in the elderly: predictors of dementia. Neurology. 1991;41(7):1006-1009. [pmid: 2067629].
Foster NL. The development of biological markers for the diagnosis of Alzheimer's disease. Neurobiol Aging. 1998;19(2):127-129. [pmid: 9558147].
Foster NL, Chase TN, Fedio P, et al. Alzheimer's disease: focal cortical changes shown by positron emission tomography. Neurology. 1983;33(8):961-965. [pmid: 6603596].
Fox NC, Rossor MN. Diagnosis of early Alzheimer's disease. Rev Neurol (Paris). Suppl 4. 1999;155:S33-S37. [pmid: 10637936].
Frackowiak RS, Pozzilli C, Legg NJ, et al. Regional cerebral oxygen supply and utilization in dementia. A clinical and physiological study with oxygen-15 and positron tomography. Brain. 1981;104(Pt 4):753-778. [pmid: 6976816].
Franceschi M, Alberoni M, Bressi S, et al. Correlations between cognitive impairment, middle cerebral artery flow velocity and cortical glucose metabolism in the early phase of Alzheimer's disease. Dementia. 1995;6(1):32-38. [pmid: 7728217].
Freter S, Bergman H, Gold S, et al. Prevalence of potentially reversible dementias and actual reversibility in a memory clinic cohort. CMAJ. 1998;159(6):657-662. [pmid: 9780965].
Friedland RP. Positron imaging in dementing illnesses. J Neuropsychiatry Clin Neurosci. 1989;1(1):S56-S60. [pmid: 2535422].
Friedland RP, Brun A, Budinger TF. Pathological and positron emission tomographic correlations in Alzheimer's disease. Lancet. 1985;1(8422):228. [pmid: 2857310].
Friedland RP, Budinger TF, Brant-Zawadzki M, et al. The diagnosis of Alzheimer-type dementia. A preliminary comparison of positron emission tomography and proton magnetic resonance. JAMA. 1984;252(19):2750-2752. [pmid: 6333523].
Friedland RP, Budinger TF, Ganz E, et al. Regional cerebral metabolic alterations in dementia of the Alzheimer type: positron emission tomography with [18F]fluorodeoxyglucose. J Comput Assist Tomogr. 1983;7(4):590-598. [pmid: 6602819].
Friedland RP, Horwitz B, Koss E. Measurement of disease progression in Alzheimer's disease. Neurobiol Aging. 1988;9(1):95-97. [pmid: 3132624].
Frisoni GB, Beltramello A, Geroldi C, et al. Brain atrophy in frontotemporal dementia. J Neurol Neurosurg Psychiatry. 1996;61(2):157-165. [pmid: 8708683].
Frisoni GB, Bianchetti A, Trabucchi M, et al. SPECT and dementia. Neurology. 1992;42(9):1850-1851. [pmid: 1513491].
Friston KJ, Frith CD, Liddle PF, et al. Comparing functional (PET) images: the assessment of significant change. J Cerebral Blood Flow Metabol. 1991;11(4):690-699.
Frolich L, Maurer K, Eilles C, et al. Diagnostic value of HMPAO-SPECT and topographic analysis of EEG in dementia of Alzheimer type. Clin Neuropharmacol. Suppl 1 Pt A. 1992;15:192A-193A.
Frost JJ. Receptor imaging by PET and SPECT: focus on the opiate receptor. J Recept Res. 1993;13(1–4):39-53. [pmid: 8095556].
Galynker II, Dutta E, Vilkas N, et al. Hypofrontality and negative symptoms in patients with dementia of Alzheimer type. Neuropsychiatry Neuropsychol Behav Neurol. 2000;13(1):53-59. [pmid: 10645737].
Gauthier S. Practical guidelines for the antemortem diagnosis of senile dementia of the Alzheimer type. Prog Neuropsychopharmacol Biol Psychiatry. 1985;9(5–6):491-495. [pmid: 3911281].
Gauthier S, Robitaille Y, Quirion R, et al. Antemortem laboratory diagnosis of Alzheimer's disease. Prog Neuropsychopharmacol Biol Psychiatry. 1986;10(3–5):391-403. [pmid: 3541044].
Gemmell HG, Sharp PF, Besson JA, et al. Differential diagnosis in dementia using the cerebral blood flow agent 99mTc HM-PAO: a SPECT study. J Comput Assist Tomogr. 1987;11(3):398-402. [pmid: 3494754].
Gemmell HG, Sharp PF, Evans NT, et al. Single photon emission tomography with 123I-isopropylamphetamine in Alzheimer's disease and multi-infarct dementia. Lancet. 1984;2(8415):1348. [pmid: 6150361].
Getsios D, Caro JJ, Caro G, et al. Assessment of health economics in Alzheimer's disease (AHEAD): galantamine treatment in Canada. Neurology. 2001;57(6):972-978. [pmid: 11571319].
Giacometti AR, Davis PC, Alazraki NP, et al. Anatomic and physiologic imaging of Alzheimer's disease. Clin Geriatr Med. 1994;10(2):277-298. [pmid: 8039099].
Grady CL, Haxby JV, Horwitz B, et al. Neuropsychological and cerebral metabolic function in early vs late onset dementia of the Alzheimer type. Neuropsychologia. 1987;25(5):807-816. [pmid: 3501553].
Grady CL, Haxby JV, Schapiro MB, et al. Subgroups in dementia of the Alzheimer type identified using positron emission tomography. J Neuropsychiatry Clin Neurosci. 1990;2(4):373-384. [pmid: 2136389].
Groom GN, Junck L, Foster NL, et al. PET of peripheral benzodiazepine binding sites in the microgliosis of Alzheimer's disease. J Nucl Med. 1995;36(12):2207-2210. [pmid: 8523106].
Grundman M, Kim HT. Iqbal K, Sisodia SS, Winblad B, editors. The Alzheimer's Disease Center's neuropsychological database initiative. Alzheimer's Disease:Advances in Etiology, Pathogenesis and Therapeutics. New York. John Wiley and Sons Ltd. 2001.
Grunwald F, Zierz S, Broich K, et al. HMPAO-SPECT imaging resembling Alzheimer-type dementia in mitochondrial encephalomyopathy with lactic acidosis and stroke-like episodes (MELAS). J Nucl Med. 1990;31(10):1740-1742. [pmid: 2213201].
Gurwitz D. Immunization for Alzheimer's disease: yet closer to clinical trials. Trends Molec Med. 2001;7(9):385. [pmid: 11530319].
Guze BH, Baxter LR Jr, Schwartz JM, et al. Changes in glucose metabolism in dementia of the Alzheimer type compared with depression: a preliminary report. Psychiatry Res. 1991;40(3):195-202. [pmid: 1780392].
Guze BH, Hoffman JM, Baxter LR, et al. Functional brain imaging and Alzheimer-type dementia. Alzheimer Dis Assoc Disord. 1991;5(4):215-230. [pmid: 1781964].
Guze BH, Hoffman JM, Mazziotta JC, et al. Positron emission tomography and familial Alzheimer's disease: a pilot study. J Am Geriatr Soc. 1992;40(2):120-123. [pmid: 1740595].
Hamilton D, O'Mahony D, Coffey J, et al. Classification of mild Alzheimer's disease by artificial neural network analysis of SPET data. Nucl Med Commun. 1997;18(9):805-810. [pmid: 9352545].
Hanyu H, Abe S, Arai H, et al. Diagnostic accuracy of single photon emission computed tomography in Alzheimer's disease. Gerontology. 1993;39(5):260-266. [pmid: 8314092].
Harris GJ, Lewis RF, Satlin A, et al. Dynamic susceptibility contrast MR imaging of regional cerebral blood volume in Alzheimer disease: a promising alternative to nuclear medicine. Am J Neuroradiol. 1998;19(9):1727-1732. [pmid: 9802497].
Haupt WF, Dietz E, Mielke R, et al. Visual evoked potentials in Alzheimer's disease: investigations in a PET-defined collective. Int J Neurosci. 1994;79(1–2):59-66. [pmid: 7744551].
Haxby JV, Grady CL, Koss E, et al. Longitudinal study of cerebral metabolic asymmetries and associated neuropsychological patterns in early dementia of the Alzheimer type. Arch Neurol. 1990;47(7):753-760. [pmid: 2357155].
Hegerl U, Moller HJ. Electroencephalography as a diagnostic instrument in Alzheimer's disease: reviews and perspectives. Int Psychogeriatr. Suppl 1. 1997;9:237-246. [pmid: 9447445].
Heiss WD, Herholz K, Pawlik G, et al. Positron emission tomography findings in dementia disorders: contributions to differential diagnosis and objectivizing of therapeutic effects. Keio J Med. 1989;38(2):111-135. [pmid: 2674513].
Heiss WD, Kessler J, Szelies B, et al. Positron emission tomography in the differential diagnosis of organic dementias. J Neural Transm. Suppl. 1991;33:13-19.
Hellman RS, Tikofsky RS, Van Heertum R, et al. A multi-institutional study of inter-observer agreement in the evaluation of dementia with rCBF/SPET technetium-99m exametazime (HMPAO). Eur J Nucl Med. 1994;21(4):306-313. [pmid: 8005154].
Herholz K. Criteria for the diagnosis of Alzheimer's Disease with Positron Emission Tomography. Dementia. 1990;(1):156-164.
Herholz K. FDG PET and differential diagnosis of dementia. Alzheimer Dis Assoc Disord. 1995;9(1):6-16. [pmid: 7605624].
Herholz K, Nordberg A, Salmon E, et al. Impairment of neocortical metabolism predicts progression in Alzheimer's disease. Dement Geriatr Cogn Disord. 1999;10(6):494-504. [pmid: 10559566].
Herholz K, Perani D, Salmon E, et al. Comparability of FDG PET studies in probable Alzheimer's disease. J Nucl Med. 1993;34(9):1460-1466. [pmid: 8355064].
Higuchi M, Arai H, Nakagawa T, et al. Regional cerebral glucose utilization is modulated by the dosage of apolipoprotein E type 4 allele and alpha1-antichymotrypsin type A allele in Alzheimer's disease. Neuroreport. 1997;8(12):2639-2643. [pmid: 9295092].
Higuchi M, Tashiro M, Arai H, et al. Glucose hypometabolism and neuropathological correlates in brains of dementia with Lewy bodies. Exp Neurol. 2000;162(2):247-256. [pmid: 10739631].
Hill TC, Holman BL. Discriminant function analysis: toward a more rigorous approach to SPECT interpretation. J Nucl Med. 1994;35(9):1455-1456. [pmid: 8071691].
Hirono N, Ishii K, Sasaki M, et al. Features of regional cerebral glucose metabolism abnormality in corticobasal degeneration. Dement Geriatr Cogn Disord. 2000;11(3):139-146. [pmid: 10765044].
Hirono N, Mori E, Ishii K, et al. Neuronal substrates for semantic memory: a positron emission tomography study in Alzheimer's disease. Dement Geriatr Cogn Disord. 2001;12(1):15-21. [pmid: 11125237].
Hirono N, Mori E, Yasuda M, et al. Lack of association of apolipoprotein E epsilon4 allele dose with cerebral glucose metabolism in Alzheimer disease. Alzheimer Dis Assoc Disord. 1998;12(4):362-367. [pmid: 9876966].
Hirsch C, Bartenstein P, Minoshima S, et al. Reduction of regional cerebral blood flow and cognitive impairment in patients with Alzheimer's disease: evaluation of an observer-independent analytic approach. Dement Geriatr Cogn Disord. 1997;8(2):98-104. [pmid: 9065322].
Hoffman JM, Guze BH, Baxter LR, et al. [18F]-fluorodeoxyglucose (FDG) and positron emission tomography (PET) in aging and dementia. A decade of studies. Eur Neurol. Suppl 3. 1989;29:16-24. [pmid: 2693102].
Hoffman JM, Welsh-Bohmer KA, Hanson M, et al. FDG PET imaging in patients with pathologically verified dementia. J Nucl Med. 2000;41(11):1920-1928. [pmid: 11079505].
Hogh P, Knudsen GM, Kjaer KH, et al. Single photon emission computed tomography and apolipoprotein E in Alzheimer's disease: impact of the epsilon4 allele on regional cerebral blood flow. J Geriatr Psychiatry Neurol. 2001;14(1):42-51. [pmid: 11281316].
Holman BL. Perfusion and receptor SPECT in the dementias--George Taplin memorial lecture. J Nucl Med. 1986;27(6):855-860. [pmid: 3519903].
Holman BL, Johnson KA, Gerada B, et al. The scintigraphic appearance of Alzheimer's disease: a prospective study using technetium-99m-HMPAO SPECT. J Nucl Med. 1992;33(2):181-185. [pmid: 1732438].
Holroyd S, Snustad DG, Chalifoux ZL. Attitudes of older adults' on being told the diagnosis of Alzheimer's disease. J Am Geriatr Soc. 1996;44(4):400-403. [pmid: 8636584].
Houston AS, Kemp PM, Macleod MA, et al. Use of significance image to determine patterns of cortical blood flow abnormality in pathological and at-risk groups. J Nucl Med. 1998;39(3):425-430. [pmid: 9529286].
Ichimiya A. Functional and structural brain imagings in dementia. Psychiatry Clin Neurosci. Suppl. 1998;52:S223-S225. [pmid: 9895152].
Ihl R, Eilles C, Frlich L, et al. Electrical brain activity and cerebral blood flow in dementia of the Alzheimer type. Psychiatry Res. 1989;29(3):449-452. [pmid: 2608817].
Irwig L, Macaskill P, Glasziou P, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. 1995;48(1):119-130. [pmid: 7853038].
Ishibashi K, Tanaka K, Nakabayashi T, et al. Latent cerebral artery stenoses on magnetic resonance angiography in a patient diagnosed as probable Alzheimer disease. Psychiatry Clin Neurosci. 1998;52(1):93-96. [pmid: 9682940].
Ishii K, Imamura T, Sasaki M, et al. Regional cerebral glucose metabolism in dementia with Lewy bodies and Alzheimer's disease. Neurology. 1998;51(1):125-130. [pmid: 9674790].
Ishii K, Kitagaki H, Kono M, et al. Decreased medial temporal oxygen metabolism in Alzheimer's disease shown by PET. J Nucl Med. 1996;37(7):1159-1165. [pmid: 8965188].
Ishii K, Mori E, Kitagaki H, et al. The clinical utility of visual evaluation of scintigraphic perfusion patterns for Alzheimer's disease using I-123 IMP SPECT. Clin Nucl Med. 1996;21(2):106-110. [pmid: 8697677].
Ishii K, Sakamoto S, Sasaki M, et al. Cerebral glucose metabolism in patients with frontotemporal dementia. J Nucl Med. 1998;39(11):1875-1878. [pmid: 9829574].
Ishii K, Sasaki M, Kitagaki H, et al. Reduction of cerebellar glucose metabolism in advanced Alzheimer's disease. J Nucl Med. 1997;38(6):925-928. [pmid: 9189143].
Ishii K, Sasaki M, Matsui M, et al. A diagnostic method for suspected Alzheimer's disease using H(2)15O positron emission tomography perfusion Z score. Neuroradiology. 2000;42(11):787-794. [pmid: 11151682].
Ishii K, Sasaki M, Yamaji S, et al. Demonstration of decreased posterior cingulate perfusion in mild Alzheimer's disease by means of H215O positron emission tomography. Eur J Nucl Med. 1997;24(6):670-673. [pmid: 9169576].
Jagust W, Thisted R, Devous MD Sr, et al. SPECT perfusion imaging in the diagnosis of Alzheimer's disease: a clinical-pathologic study. Neurology. 2001;56(7):950-956. [pmid: 11294935].
Jagust WJ. Functional imaging in dementia: an overview. J Clin Psychiatry. Suppl. 1994;55:5-11. [pmid: 7989292].
Jagust WJ, Budinger TF, Huesman RH, et al. Methodologic factors affecting PET measurements of cerebral glucose metabolism. J Nucl Med. 1986;27(8):1358-1361. [pmid: 3488379].
Jagust WJ, Eberling JL. MRI, CT, SPECT, PET: their use in diagnosing dementia. Geriatrics. 1991;46(2):28-35. [pmid: 1991619].
Jagust WJ, Eberling JL, Richardson BC, et al. The cortical topography of temporal lobe hypometabolism in early Alzheimer's disease. Brain Res. 1993;629(2):189-198. [pmid: 8111623].
Jagust WJ, Friedland RP, Budinger TF. Positron emission tomography with [18F]fluorodeoxyglucose differentiates normal pressure hydrocephalus from Alzheimer-type dementia. J Neurol Neurosurg Psychiatry. 1985;48(11):1091-1096. [pmid: 3878390].
Jagust WJ, Friedland RP, Budinger TF, et al. Longitudinal studies of regional cerebral metabolism in Alzheimer's disease. Neurology. 1988;38(6):909-912. [pmid: 3259296].
Jagust WJ, Haan MN, Reed BR, et al. Brain perfusion imaging predicts survival in Alzheimer's disease. Neurology. 1998;51(4):1009-1013. [pmid: 9781521].
Jagust WJ, Johnson KA, Holman BL. SPECT perfusion imaging in the diagnosis of dementia. J Neuroimaging. Suppl 1. 1995;5:S45-S52. [pmid: 7626837].
Jelic V, Nordberg A. Early diagnosis of Alzheimer disease with positron emission tomography. Alzheimer Dis Assoc Disord. Suppl 1. 2000;14:S109-S113. [pmid: 10850738].
Jellinger KA. Positron emission tomography in vascular dementia. J Neurol Sci. 1998;160(2):190-191. [pmid: 9849806].
Jobst KA, Barnetson LP, Shepstone BJ. Accurate prediction of histologically confirmed Alzheimer's disease and the differential diagnosis of dementia: the use of NINCDS-ADRDA and DSM-III-R criteria, SPECT, X-ray CT, and Apo E4 in medial temporal lobe dementias. Oxford Project to Investigate Memory and Aging. Int Psychogeriatr. 1998;10(3):271-302. [pmid: 9785148].
Jobst KA, Hindley NJ, King E, et al. The diagnosis of Alzheimer's disease: a question of image. J Clin Psychiatry. Suppl. 1994;55:22-31. [pmid: 7989291].
Jobst KA, Smith AD, Barker CS, et al. Association of atrophy of the medial temporal lobe with reduced blood flow in the posterior parietotemporal cortex in patients with a clinical and pathological diagnosis of Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1992;55(3):190-194. [pmid: 1564478].
Johnson KA, Jones K, Holman BL, et al. Preclinical prediction of Alzheimer's disease using SPECT. Neurology. 1998;50(6):1563-1571. [pmid: 9633695].
Jonkman EJ. The role of the electroencephalogram in the diagnosis of dementia of the Alzheimer type: an attempt at technology assessment. Neurophysiol Clin. 1997;27(3):211-219. [pmid: 9260162].
Julin P, Lindqvist J, Svensson L, et al. MRI-guided SPECT measurements of medial temporal lobe blood flow in Alzheimer's disease. J Nucl Med. 1997;38(6):914-919. [pmid: 9189141].
Julin P, Wahlund LO, Basun H, et al. Clinical diagnosis of frontal lobe dementia and Alzheimer's disease: relation to cerebral perfusion, brain atrophy and electroencephalography. Dementia. 1995;6(3):142-147. [pmid: 7620526].
Katzman R. Alzheimer's disease. N Engl J Med. 1986;314(15):964-973. [pmid: 2870433].
Katzman R. Iqbal K, Sisodia S, Winbald B, editors. Alzheimer's disease: Epidemiologiy of Alzheimer's disease and dementia: advances and challenges. Advances in etiology, pathogenesis and therapeutics. New York. John Wiley and Sons, Ltd. 2001.
Kennedy AM, Frackowiak RS, Newman SK, et al. Deficits in cerebral glucose metabolism demonstrated by positron emission tomography in individuals at risk of familial Alzheimer's disease. Neurosci Lett. 1995;186(1):17-20. [pmid: 7783942].
Kennedy AM, Rossor MN, Frackowiak RS. Positron emission tomography in familial Alzheimer disease. Alzheimer Dis Assoc Disord. 1995;9(1):17-20. [pmid: 7605617].
Kessler J, Herholz K, Grond M, et al. Impaired metabolic activation in Alzheimer's disease: a PET study during continuous visual recognition. Neuropsychologia. 1991;29(3):229-243. [pmid: 2057055].
Khachaturian ZS. Diagnosis of Alzheimer's disease. Arch Neurol. 1985;42(11):1097-1105. [pmid: 2864910].
Killen AR, Oster G, Colditz GA. An assessment of the role of 123I-N-isopropyl-piodoamphetamine with single-photon emission computed tomography in the diagnosis of stroke and Alzheimer's disease. Nucl Med Commun. 1989;10(4):271-284. [pmid: 2662071].
Kippenhan JS, Barker WW, Nagel J, et al. Neural-network classification of normal and Alzheimer's disease subjects using high-resolution and low-resolution PET cameras. J Nucl Med. 1994;35(1):7-15. [pmid: 8271062].
Kippenhan JS, Barker WW, Pascal S, et al. Evaluation of a neural-network classifier for PET scans of normal and Alzheimer's disease subjects. J Nucl Med. 1992;33(8):1459-1467. [pmid: 1634935].
Kitagaki H, Mori E, Yamaji S, et al. Frontotemporal dementia and Alzheimer disease: evaluation of cortical atrophy with automated hemispheric surface display generated with MR images. Radiology. 1998;208(2):431-439. [pmid: 9680572].
Knopman DS, DeKosky ST, Cummings JL, et al. Practice parameter: diagnosis of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1143-1153. [pmid: 11342678].
Kondo M, Imahori Y, Mori S, et al. Aberrant plasticity in Alzheimer's disease. Neuroreport. 1999;10(7):1481-1484. [pmid: 10380966].
Kondoh Y, Nagata K, Sasaki H, et al. Dynamic FDG-PET study in probable Alzheimer's disease. Ann N Y Acad Sci. 1997;826:406-409. [pmid: 9329713].
Kotrla KJ, Chacko RC, Harper RG, et al. SPECT findings on psychosis in Alzheimer's disease. Am J Psychiatry. 1995;152(10):1470-1475. [pmid: 7573586].
Krausz Y, Bonne O, Marciano R, et al. Brain SPECT imaging of neuropsychiatric disorders. Eur J Radiol. 1996;21(3):183-187. [pmid: 8777908].
Kuhl DE, Metter EJ, Riege WH, et al. Determinations of cerebral glucose utilization in dementia using positron emission tomography. Dan Med Bull. Suppl 1. 1985;32:51-55. [pmid: 3872772].
Kumar A, Schapiro MB, Grady C, et al. High-resolution PET studies in Alzheimer's disease. Neuropsychopharmacology. 1991;4(1):35-46. [pmid: 2003867].
Kuwabara Y, Ichiya Y, Otsuka M, et al. Differential diagnosis of bilateral parietal abnormalities in I-123 IMP SPECT imaging. Clin Nucl Med. 1990;15(12):893-899. [pmid: 2276232].
Kwa VI, Weinstein HC, Posthumus Meyjes EF, et al. Spectral analysis of the EEG and 99m-Tc-HMPAO SPECT-scan in Alzheimer's disease. Biol Psychiatry. 1993;33(2):100-107. [pmid: 8439599].
Larson EB, Kukull WA, Katzman RL. Cognitive impairment: dementia and Alzheimer's disease. Annual Rev Publ Health. 1992;13:431-449.
Lau J, Ioannidis JPA, Balk E, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments. Evidence Report/Technology Assessment No. 26. Available at Agency for Healthcare Research and Quality website. Accessed December 6, 2001. Available at http://www.ahrq.gov.
Launes J, Sulkava R, Erkinjuntti T, et al. 99Tcm-HMPAO SPECT in suspected dementia. Nucl Med Commun. 1991;12(9):757-765. [pmid: 1945187].
Lautenschlager NT, Cupples LA, Rao VS, et al. Risk of dementia among relatives of Alzheimer's disease patients in the MIRAGE study: What is in store for the oldest old. Neurology. 1996;46(3):641-650. [pmid: 8618660].
Lavenu I, Pasquier F, Lebert F, et al. Association between medial temporal lobe atrophy on CT and parietotemporal uptake decrease on SPECT in Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1997;63(4):441-445. [pmid: 9343120].
Lehtovirta M, Kuikka J, Helisalmi S, et al. Longitudinal SPECT study in Alzheimer's disease: relation to apolipoprotein E polymorphism. J Neurol Neurosurg Psychiatry. 1998;64(6):742-746. [pmid: 9647302].
Lehtovirta M, Soininen H, Laakso MP, et al. SPECT and MRI analysis in Alzheimer's disease: relation to apolipoprotein E epsilon 4 allele. J Neurol Neurosurg Psychiatry. 1996;60(6):644-649. [pmid: 8648331].
Lindau M, Almkvist O, Kushi J, et al. First symptoms--frontotemporal dementia versus Alzheimer's disease. Dement Geriatr Cogn Disord. 2000;11(5):286-293. [pmid: 10940680].
Links JM, Devous MD. Detection and comparison of patterns in images. J Nucl Med. 1994;35(1):16-17. [pmid: 8271039].
Liu HG, Mountz JM, Inampudi C, et al. A semiquantitative cortical circumferential normalization method for clinical evaluation of rCBF brain SPECT. Clin Nucl Med. 1997;22(9):596-604. [pmid: 9298292].
Liu SJ, Crum RM, Anthony JC. A latent variable approach to studying risk factors for Alzheimer's disease. Neuroepidemiology. 2001;20(1):31-39. [pmid: 11174043].
Loeb C. Clinical criteria for the diagnosis of vascular dementia. Eur Neurol. 1988;28(2):87-92. [pmid: 3131146].
Lowers J. MR and PET vie in diagnosis of Alzheimer's disease. Diagn Imaging (San Franc). 2000;22(11):113-116. [pmid: 11148954].
Maas LC, Harris GJ, Satlin A, et al. Regional cerebral blood volume measured by dynamic susceptibility contrast MR imaging in Alzheimer's disease: a principal components analysis. J Magn Reson Imaging. 1997;7(1):215-219. [pmid: 9039618].
Mann UM, Mohr E, Gearing M, et al. Heterogeneity in Alzheimer's disease: progression rate segregated by distinct neuropsychological and cerebral metabolic profiles. J Neurol Neurosurg Psychiatry. 1992;55(10):956-959. [pmid: 1431960].
Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioral family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. 2000;176:557-562. [pmid: 10974962].
Marsh JT, Schubarth G, Brown WS, et al. PET and P300 relationships in early Alzheimer's disease. Neurobiol Aging. 1990;11(4):471-476. [pmid: 2381507].
Masterman DL, Mendez MF, Fairbanks LA, et al. Sensitivity, specificity, and positive predictive value of technetium 99-HMPAO SPECT in discriminating Alzheimer's disease from other dementias. J Geriatr Psychiatry Neurol. 1997;10(1):15-21. [pmid: 9100154].
Matsuzawa T, Meguro K, Ueda M, et al. Dementia syndrome and the onset of mind. Sci Rep Res Inst Tohoku Univ [Med]. 1988;35(1–4):29-34.
Mattman A, Feldman H, Forster B, et al. Regional HmPAO SPECT and CT measurements in the diagnosis of Alzheimer's disease. Can J Neurol Sci. 1997;24(1):22-28. [pmid: 9043743].
Mayberg HS. Clinical correlates of PET- and SPECT-identified defects in dementia. J Clin Psychiatry. Suppl. 1994;55:12-21. [pmid: 7989290].
Mayeux R, Sano M, Chen J, et al. Risk of dementia in first-degree relatives of patients with Alzheimer's disease and related disorders. Arch Neurol. 1991;48(3):269-273. [pmid: 2001183].
Mayeux R, Schupf N. Apolipoprotein E and Alzheimer's disease: the implications of progress in molecular medicine. Am J Publ Health. 1995;85(9):1280-1284.
Mazziotta JC, Frackowiak RS, Phelps ME. The use of positron emission tomography in the clinical assessment of dementia. Sem Nucl Med. 1992;22(4):233-246.
McCrory SJ, Ford I. Multivariate analysis of SPECT images with illustrations in Alzheimer's disease. Stat Med. 1991;10(11):1711-1718. [pmid: 1792465].
McGeer PL. Brain imaging in Alzheimer's disease. Br Med Bull. 1986;42(1):24-28. [pmid: 3513888].
McGeer PL, Kamo H, Harrop R, et al. Positron emission tomography in patients with clinically diagnosed Alzheimer's disease. CMAJ. 1986;134(6):597-607. [pmid: 3512063].
McGeer PL, Kamo H, Harrop R, et al. Comparison of PET, MRI, and CT with pathology in a proven case of Alzheimer's disease. Neurology. 1986;36(12):1569-1574. [pmid: 3491344].
McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34(7):939-944. [pmid: 6610841].
McMahon PM, Araki SS, Neumann PJ, et al. Cost-effectiveness of functional imaging tests in the diagnosis of Alzheimer disease. Radiology. 2000;217(1):58-68. [pmid: 11012424].
McNair N. Horizons. Use of PET in diagnosing Alzheimer's disease. J Neurosci Nurs. 1996;28(4):275.
Medicare Coverage Advisory Committee. Medicare Coverage Policy ~ MCAC. Available at MCAC website. Available at http:www.hcfa.gov/coverage/8b1.htm. Accessed December 6, 2001.
Meltzer CC, Leal JP, Mayberg HS, et al. Correction of PET data for partial volume effects in human cerebral cortex by MR imaging. J Comput Assist Tomogr. 1990;14(4):561-570. [pmid: 2370355].
Mentis MJ, Alexander GE, Krasuski J, et al. Increasing required neural response to expose abnormal brain function in mild versus moderate or severe Alzheimer's disease: PET study using parametric visual stimulation. Am J Psychiatry. 1998;155(6):785-794. [pmid: 9619151].
Messa C, Perani D, Lucignani G, et al. High-resolution technetium-99m-HMPAO SPECT in patients with probable Alzheimer's disease: comparison with fluorine-18-FDG PET. J Nucl Med. 1994;35(2):210-216. [pmid: 8294987].
Mielke R, Heiss WD. Positron emission tomography for diagnosis of Alzheimer's disease and vascular dementia. J Neural Transm. Suppl. 1998;53:237-250.
Mielke R, Herholz K, Grond M, et al. Differences of regional cerebral glucose metabolism between presenile and senile dementia of Alzheimer type. Neurobiol Aging. 1992;13(1):93-98. [pmid: 1542386].
Mielke R, Herholz K, Grond M, et al. Clinical deterioration in probable Alzheimer's disease correlates with progressive metabolic impairment of association areas. Dementia. 1994;5(1):36-41. [pmid: 8156085].
Mielke R, Pietrzyk U, Jacobs A, et al. HMPAO SPET and FDG PET in Alzheimer's disease and vascular dementia: comparison of perfusion and metabolic pattern. Eur J Nucl Med. 1994;21(10):1052-1060. [pmid: 7828614].
Mielke R, Schroder R, Fink GR, et al. Regional cerebral glucose metabolism and postmortem pathology in Alzheimer's disease. Acta Neuropathol. 1996;91(2):174-179. [pmid: 8787151].
Miller BL, Darby AL, Swartz JR, et al. Dietary changes, compulsions and sexual behavior in frontotemporal degeneration. Dementia. 1995;6(4):195-199. [pmid: 7550598].
Miller BL, Ikonte C, Ponton M, et al. A study of the Lund-Manchester research criteria for frontotemporal dementia: clinical and single-photon emission CT correlations. Neurology. 1997;48(4):937-942. [pmid: 9109881].
Minoshima S, Frey KA, Foster NL, et al. Preserved pontine glucose metabolism in Alzheimer disease: a reference region for functional brain image (PET) analysis. J Comput Assist Tomogr. 1995;19(4):541-547. [pmid: 7622680].
Minoshima S, Frey KA, Koeppe RA, et al. A diagnostic approach in Alzheimer's disease using three-dimensional stereotactic surface projections of fluorine-18-FDG PET. J Nucl Med. 1995;36(7):1238-1248. [pmid: 7790950].
Mittelman MS, Ferris SH, Shulman E, et al. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. 1996;276(21):1725-1731. [pmid: 8940320].
Mohr E, Feldman H, Gauthier S. Canadian guidelines for the development of antidementia therapies: a conceptual summary. Can J Neurol Sci. 1995;22(1):62-71. [pmid: 7750079].
Mohs RC, Breitner JC, Silverman JM, et al. Alzheimer's disease. Morbid risk among first-degree relatives approximates 50% by 90 years of age. Arch Gen Psychiatry. 1987;44(5):405-408. [pmid: 3579492].
Mohs RC, Doody RS, Morris JC, et al. A 1-year, placebo-controlled preservation of function survival study of donepezil in Alzheimer's disease patients. Neurology. 2001;57(1):481-488. [pmid: 11502917].
Montplaisir J, Petit D, McNamara D, et al. Comparisons between SPECT and quantitative EEG measures of cortical impairment in mild to moderate Alzheimer's disease. Eur Neurol. 1996;36(4):197-200. [pmid: 8814420].
Morris JC, McKeel DW Jr, Storandt M, et al. Very mild Alzheimer's disease: informant-based clinical, psychometric, and pathologic distinction from normal aging. Neurology. 1991;41(4):469-478. [pmid: 2011242].
Morris JC, Storandt M, Miller JP, et al. Mild cognitive impairment represents early-stage Alzheimer disease. Arch Neurol. 2001;58(3):397-405. [pmid: 11255443].
Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293-1316. [pmid: 8210827].
Muller H, Moller HJ, Stippel A, et al. SPECT patterns in probable Alzheimer's disease. Eur Arch Psychiatry Clin Neurosci. 1999;249(4):190-196. [pmid: 10449594].
Nagata K, Maruya H, Yuya H, et al. Can PET data differentiate Alzheimer's disease from vascular dementia. Ann N Y Acad Sci. 2000;903:252-261. [pmid: 10818514].
Nagy Z, Hindley NJ, Braak H, et al. Relationship between clinical and radiological diagnostic criteria for Alzheimer's disease and the extent of neuropathology as reflected by 'stages': a prospective study. Dement Geriatr Cogn Disord. 1999;10(2):109-114. [pmid: 10026384].
National Center for Health Statistics. Death rates by 10-year age groups and age-adjusted death rates for Alzheimer's disease, by race and sex, United States, 1979–98. Available at National Center for Health Statistics website. Available at: http:www.cdc.gov/nchs. Accessed December 6, 2001.
National Center for Health Statistics. Death rates by 10-year age groups and age-adjusted death rates for Alzheimer's disease, by race and sex: United States, 1979–98. Available at National Center for Health Statistics website. Available at http://www.cdc.gov/nchs. Accessed December 6, 2001.
Neumann PJ, Hermann RC, Kuntz KM, et al. Cost-effectiveness of donepezil in the treatment of mild or moderate Alzheimer's disease. Neurology. 1999;52(6):1138-1145. [pmid: 10214734].
Neumann PJ, Kuntz KM, Leon J, et al. Health utilities in Alzheimer's disease: a cross sectional study of patients and caregivers. Med Care. 1999;37(1):27-32. [pmid: 10413389].
Nordberg A. Clinical studies in Alzheimer patients with positron emission tomography. Behav Brain Res. 1993;57(2):215-224. [pmid: 7906947].
Nordberg A. Application of PET in dementia disorders. Acta Neurol Scand. Suppl. 1996;168:71-76.
Nordberg A. PET studies and cholinergic therapy in Alzheimer's disease. Rev Neurol (Paris). Suppl 4. 1999;155:S53-S63. [pmid: 10637939].
O'Connell RA, Van Heertum RL, Billick SB, et al. Single photon emission computed tomography (SPECT) with [123I]IMP in the differential diagnosis of psychiatric disorders. J Neuropsychiatry Clin Neurosci. 1989;1(2):145-153. [pmid: 2521055].
O'Mahony D, Coffey J, Murphy J, et al. The discriminant value of semiquantitative SPECT data in mild Alzheimer's disease. J Nucl Med. 1994;35(9):1450-1455. [pmid: 8071690].
Ohyama M, Senda M, Ishiwata K, et al. Preserved benzodiazepine receptors in Alzheimer's disease measured with C-11 flumazenil PET and I-123 iomazenil SPECT in comparison with CBF. Ann Nucl Med. 1999;13(5):309-315. [pmid: 10582800].
Ohyama M, Senda M, Mishina M, et al. Semi-automatic ROI placement system for analysis of brain PET images based on elastic model: application to diagnosis of Alzheimer's disease. Keio J Med. Suppl 1. 2000;49:A105-A106. [pmid: 10750353].
Onishi Y, Yonekura Y, Tanaka F, et al. Delayed image of iodine-123 iomazenil as a relative map of benzodiazepine receptor binding: the optimal scan time. Eur J Nucl Med. 1996;23(11):1491-1497. [pmid: 8854848].
Osimani A, Ichise M, Chung DG, et al. SPECT for differential diagnosis of dementia and correlation of rCBF with cognitive impairment. Can J Neurol Sci. 1994;21(2):104-111. [pmid: 8087734].
Ott BR, Faberman RS, Noto RB, et al. A SPECT imaging study of MRI white matter hyperintensity in patients with degenerative dementia. Dement Geriatr Cogn Disord. 1997;8(6):348-354. [pmid: 9370087].
Ott BR, Noto RB. Sensitivity of SPECT for the diagnosis of Alzheimer's disease. Clin Gerontol. 2000;22(1):73-82.
Page MP, Howard RJ, O'Brien JT, et al. Use of neural networks in brain SPECT to diagnose Alzheimer's disease. J Nucl Med. 1996;37(2):195-200. [pmid: 8667044].
Parnetti L, Lowenthal DT, Presciutti O, et al. 1H-MRS, MRI-based hippocampal volumetry, and 99mTc-HMPAO-SPECT in normal aging, age-associated memory impairment, and probable Alzheimer's disease. J Am Geriatr Soc. 1996;44(2):133-138. [pmid: 8576501].
Patterson CJ, Gass DA. Screening for cognitive impairment and dementia in the elderly. Can J Neurol Sci. Suppl 1. 2001;28:S42-S51. [pmid: 11237310].
Pavics L, Grunwald F, Reichmann K, et al. Regional cerebral blood flow single-photon emission tomography with 99mTc-HMPAO and the acetazolamide test in the evaluation of vascular and Alzheimer's dementia. Eur J Nucl Med. 1999;26(3):239-245. [pmid: 10079314].
Pearlson GD, Harris GJ, Powers RE, et al. Quantitative changes in mesial temporal volume, regional cerebral blood flow, and cognition in Alzheimer's disease. Arch Gen Psychiatry. 1992;49(5):402-408. [pmid: 1586276].
Pedro-Botet J, Rubies-Part J. Positron-emission tomography and Alzheimer's disease. N Engl J Med. 1996;335(3):207-208. [pmid: 8657229].
Penniello MJ, Lambert J, Eustache F, et al. A PET study of the functional neuroanatomy of writing impairment in Alzheimer's disease. The role of the left supramarginal and left angular gyri. Brain. 1995;118(Pt 3):697-706. [pmid: 7600087].
Petersen RC, Smith GE, Waring SC, et al. Mild cognitive impairment: clinical characterization and outcome. Arch Neurol. 1999;56(3):303-308. [pmid: 10190820].
Petersen RC, Stevens JC, Ganguli M, et al. Practice parameter: early detection of dementia: mild cognitive impairment (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1133-1142. [pmid: 11342677].
Phelps ME. PET: the merging of biology and imaging into molecular imaging. J Nucl Med. 2000;41(4):661-681. [pmid: 10768568].
Philbrick KL, Rummans TA, Duffy JR, et al. Primary progressive aphasia. An uncommon masquerader of psychiatric disorders. Psychosomatics. 1994;35(2):138-141. [pmid: 8171172].
Pickut BA, Saerens J, Marien P, et al. Discriminative use of SPECT in frontal lobe-type dementia versus (senile) dementia of the Alzheimer's type. J Nucl Med. 1997;38(6):929-934. [pmid: 9189144].
Piert M, Koeppe RA, Giordani B, et al. Diminished glucose transport and phosphorylation in Alzheimer's disease determined by dynamic FDG-PET. J Nucl Med. 1996;37(2):201-208. [pmid: 8667045].
Pietrini P, Alexander GE, Furey ML, et al. Cerebral metabolic response to passive audiovisual stimulation in patients with Alzheimer's disease and healthy volunteers assessed by PET. J Nucl Med. 2000;41(4):575-583. [pmid: 10768555].
Pietrini P, Azari NP, Grady CL, et al. Pattern of cerebral metabolic interactions in a subject with isolated amnesia at risk for Alzheimer's disease: a longitudinal evaluation. Dementia. 1993;4(2):94-101. [pmid: 8358518].
Pietrini P, Dani A, Furey ML, et al. Low glucose metabolism during brain stimulation in older Down's syndrome subjects at risk for Alzheimer's disease prior to dementia. Am J Psychiatry. 1997;154(8):1063-1069. [pmid: 9247390].
Pietrini P, Furey ML, Alexander GE, et al. Association between brain functional failure and dementia severity in Alzheimer's disease: resting versus stimulation PET study. Am J Psychiatry. 1999;156(3):470-473. [pmid: 10080567].
Pietrini P, Furey ML, Graff-Radford N, et al. Preferential metabolic involvement of visual cortical areas in a subtype of Alzheimer's disease: clinical implications. Am J Psychiatry. 1996;153(10):1261-1268. [pmid: 8831432].
Poline JB, Vandenberghe R, Holmes AP, et al. Reproducibility of PET activation studies: lessons from a multi-center European experiment. EU concerted action on functional imaging. Neuroimage. 1996;4(1):34-54. [pmid: 9345495].
Post SG, Whitehouse PJ. Fairhill guidelines on ethics of the care of people with Alzheimer's disease: a clinical summary. Center for Biomedical Ethics, Case Western Reserve University and the Alzheimer's Association. J Am Geriatr Soc. 1995;43(12):1423-1429. [pmid: 7490397].
Powers WJ, Perlmutter JS, Videen TO, et al. Blinded clinical evaluation of positron emission tomography for diagnosis of probable Alzheimer's disease. Neurology. 1992;42(4):765-770. [pmid: 1565229].
Prohovnik I. Discriminant value of semiquantitative SPECT data in mild Alzheimer's disease. J Nucl Med. 1996;37(2):404. [pmid: 8667089].
Prohovnik I. Iodine-123-iomazenil SPECT in Alzheimer's disease. J Nucl Med. 1998;39(5):927. [pmid: 9591604].
Prohovnik I, Metz CD, Atkins HL. Radiation exposure to human trachea from xenon-133 procedures. J Nucl Med. 1995;36(8):1458-1461. [pmid: 7629595].
Rao DC. CAT scans, PET scans, and genomic scans. Genet Epidemiol. 1998;15(1):1-18. [pmid: 9523207].
Rappaport SI. In vivo PET imaging and postmortem studies suggest potentially reversible and irreversible stages of brain metabolic failure in Alzheimer's disease. Eur Arch Psychiatry Clin Neurosci. Suppl 3. 1999;249:46-55. [pmid: 10654100].
Rappaport SI. Functional brain imaging to identify affected subjects genetically at risk for Alzheimer's disease. Proc Natl Acad Sci U S A. 2000;97(11):5696-5698. [pmid: 10811924].
Rasgon N, Ananth J, Mena I, et al. Agenesis of corpus callosum and dementia of the Alzheimer's type: a review and case report. Can J Psychiatry. 1994;39(7):429-432. [pmid: 7987785].
Read SL, Miller BL, Mena I, et al. SPECT in dementia: clinical and pathological correlation. J Am Geriatr Soc. 1995;43(11):1243-1247. [pmid: 7594158].
Reiman EM, Caselli RJ, Yun LS, et al. Preclinical evidence of Alzheimer's disease in persons homozygous for the epsilon 4 allele for apolipoprotein E. N Engl J Med. 1996;334(12):752-758. [pmid: 8592548].
Reiman EM, Uecker A, Caselli RJ, et al. Hippocampal volumes in cognitively normal persons at genetic risk for Alzheimer's disease. Ann Neurol. 1998;44(2):288-291. [pmid: 9708558].
Reisberg B, Burns A, Brodaty H, et al. Diagnosis of Alzheimer's disease. Report of an International Psychogeriatric Association Special Meeting Work Group under the cosponsorship of Alzheimer's Disease International, the European Federation of Neurological Societies, the World Health Organization, and the World Psychiatric Association. Int Psychogeriatr. Supl 1. 1997;9:11-38. [pmid: 9447425].
Reischies FM, Hedde JP, Gutzmann H. The investigation of dementia syndromes by 133Xenon dynamic single photon emission computed tomography. Neurosurg Rev. 1987;10(2):105-108. [pmid: 3502360].
Riege WH, Metter EJ. Cognitive and brain imaging measures of Alzheimer's disease. Neurobiol Aging. 1988;9(1):69-86. [pmid: 3288895].
Ritchie K, Gilham C, Ledesert B, et al. Depressive illness, depressive symptomatology and regional cerebral blood flow in elderly people with sub-clinical cognitive impairment. Age & Ageing. 1999;28(4):385-391. [pmid: 10459793].
Roberts S. Anticipating response to predictive genetic testing for Alzheimer's disease: A survey of first degree relatives. The Gerontologist. 2000;40:43-52. [pmid: 10750312].
Rodriguez G, Vitali P, Calvini P, et al. Hippocampal perfusion in mild Alzheimer's disease. Psychiatry Res. 2000;100(2):65-74. [pmid: 11114492].
Roses AD. Apolipoprotein E, a gene with complex biological interactions in the aging brain. Neurobiol Dis. 1997;4(3–4):170-185. [pmid: 9361294].
Rossor MN, Kennedy AM, Frackowiak RS. Clinical and neuroimaging features of familial Alzheimer's disease. Ann N Y Acad Sci. 1996;777:49-56. [pmid: 8624126].
Rubensztein DC, Easton DF. Apolipoprotein E genetic variation and Alzheimer's disease: a meta-analysis. Dement Geriatr Cogn Disord. 1999;10:199-209. [pmid: 10325447].
Salmon E, Sadzot B, Maquet P, et al. Differential diagnosis of Alzheimer's disease with PET. J Nucl Med. 1994;35(3):391-398. [pmid: 8113882].
Salmon E, Van der Linden M, Maerfens Noordhout A, et al. Early thalamic and cortical hypometabolism in adult-onset dementia due to metachromatic leukodystrophy. Acta Neurol Belg. 1999;99(3):185-188. [pmid: 10544727].
Salmon E, Van der Linden MV, Franck G. Anterior cingulate and motor network metabolic impairment in progressive supranuclear palsy. Neuroimage. 1997;5(3):173-178. [pmid: 9345547].
Santens P, Petit H. Positron emission tomography in dementia. Acta Neurol Belg. 1997;97(3):192-195. [pmid: 9345592].
Sarangi S, San Pedro EC, Mountz JM. Anterior choroidal artery infarction presenting as a progressive cognitive deficit. Clin Nucl Med. 2000;25(3):187-190. [pmid: 10698414].
Schapiro MB, Pietrini P, Grady CL, et al. Reductions in parietal and temporal cerebral metabolic rates for glucose are not specific for Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1993;56(8):859-864. [pmid: 8350100].
Scheltens P, Launer LJ, Barkhof F, et al. The diagnostic value of magnetic resonance imaging and technetium 99m-HMPAO single-photon-emission computed tomography for the diagnosis of Alzheimer disease in a community-dwelling elderly population. Alzheimer Dis Assoc Disord. 1997;11(2):63-70. [pmid: 9194952].
Schenk D, Barbour R, Dunn W, et al. Immunization with amyloid-beta attenuates Alzheimer-disease-like pathology in the PDAPP mouse. Nature. 1999;400(6740):173-177. [pmid: 10408445].
Schwarzschild M, Rordorf G, Bekken K, et al. Normal-pressure hydrocephalus with misleading features of irreversible dementias: a case report. J Geriatr Psychiatry Neurol. 1997;10(2):51-54. [pmid: 9188018].
Scinto L, Daffner K. Early diagnosis of Alzheimer's disease. Tottowa, NJ. Humana Press. 2000.
Selkoe DJ. The cell biology of beta-amyloid precursor protein and presenilin in Alzheimer's disease. Trends Cell Biol. 1998;11:447-453. [pmid: 9854312].
Selkoe DJ. Alzheimer's disease: genes, proteins, and therapy. Physiol Rev. 2001;81(2):741-766. [pmid: 11274343].
Shinotoh H, Namba H, Fukushi K, et al. Brain acetylcholinesterase activity in Alzheimer disease measured by positron emission tomography. Alzheimer Dis Assoc Disord. Suppl 1. 2000;14:S114-S118. [pmid: 10850739].
Sigurdsson EM, Scholtzova H, Mehta PD, et al. Immunization with a nontoxic/nonfibrillar amyloid-beta homologous peptide reduces Alzheimer's disease-associated pathology in transgenic mice. Am J Pathol. 2001;159(2):439-447. [pmid: 11485902].
Silverman DH, Phelps ME. Evaluating dementia using PET: how do we put into clinical perspective what we know to date. J Nucl Med. 2000;41(11):1929-1932. [pmid: 11079506].
Silverman DH, Small GW, Chang CY, et al. Positron emission tomography in evaluation of dementia. JAMA. 2001;286(17):2120-2127. [pmid: 11694153].
Silverman JM, Li G, Zaccario ML, et al. Patterns of risk in first-degree relatives of patients with Alzheimer's disease. Arch Gen Psychiatry. 1994;51(7):577-586. [pmid: 8031231].
Sjogren M, Gustafson L, Wikkelso C, et al. Frontotemporal dementia can be distinguished from Alzheimer's disease and subcortical white matter dementia by an anterior-to-posterior rCBF-SPET ratio. Dement Geriatr Cogn Disord. 2000;11(5):275-285. [pmid: 10940679].
Small G. Early diagnosis of Alzheimer's disease. New Dir Ment Health Serv. 1997;(76):39-51. [pmid: 9520524].
Small GW. Neuroimaging and genetic assessment for early diagnosis of Alzheimer's disease. J Clin Psychiatry. Suppl 14. 1996;57:9-13. [pmid: 9024331].
Small GW. Investigations into geriatric psychiatry challenges: AAGP Senior Investigator Award 200. Am J Geriatr Psychiatry. 2000;8(4):276-283. [pmid: 11069266].
Small GW, Ercoli LM, Silverman DH, et al. Cerebral metabolic and cognitive decline in persons at genetic risk for Alzheimer's disease. Proc Natl Acad Sci U S A. 2000;97(11):6037-6042. [pmid: 10811879].
Small GW, Komo S, La Rue A, et al. Early detection of Alzheimer's disease by combining apolipoprotein E and neuroimaging. Ann N Y Acad Sci. 1996;802:70-78. [pmid: 8993486].
Small GW, Kuhl DE, Riege WH, et al. Cerebral glucose metabolic patterns in Alzheimer's disease. Effect of gender and age at dementia onset. Arch Gen Psychiatry. 1989;46(6):527-532. [pmid: 2730277].
Small GW, Leiter F. Neuroimaging for diagnosis of dementia. J Clin Psychiatry. Suppl 11. 1998;59:4-7. [pmid: 9731543].
Small GW, Leuchter AF, Mandelkern MA, et al. Clinical, neuroimaging, and environmental risk differences in monozygotic female twins appearing discordant for dementia of the Alzheimer type. Arch Neurol. 1993;50(2):209-219. [pmid: 8431141].
Small GW, Mazziotta JC, Collins MT, et al. Apolipoprotein E type 4 allele and cerebral glucose metabolism in relatives at risk for familial Alzheimer disease. JAMA. 1995;273(12):942-947. [pmid: 7884953].
Small GW, Okonek A, Mandelkern MA, et al. Age-associated memory loss: initial neuropsychological and cerebral metabolic findings of a longitudinal study. Int Psychogeriatr. 1994;6(1):23-44. [pmid: 8054492].
Smith AD, Jobst KA. Use of structural imaging to study the progression of Alzheimer's disease. Br Med Bull. 1996;52(3):575-586. [pmid: 8949258].
Soricelli A, Postiglione A, Grivet-Fojaja MR, et al. Reduced cortical distribution volume of iodine-123 iomazenil in Alzheimer's disease as a measure of loss of synapses. Eur J Nucl Med. 1996;23(10):1323-1328. [pmid: 8781136].
Souder E. A comparison of neuroimaging modalities for diagnosing dementia. Nurse Practitioner. 1995;20(1):66-74. [pmid: 7898792].
Souder E, Saykin AJ, Alavi A. Multi-modal assessment in Alzheimer's disease. ADL in relation to PET, MRI and neuropsychology. J Gerontol Nurs. 1995;21(9):7-13. [pmid: 7560823].
Spampinato U, Habert MO, Mas JL, et al. (99mTc)-HM-PAO SPECT and cognitive impairment in Parkinson's disease: a comparison with dementia of the Alzheimer type. J Neurol Neurosurg Psychiatry. 1991;54(9):787-792. [pmid: 1955897].
Stahelin HB, Monsch AU, Spiegel R. Early diagnosis of dementia via a two-step screening and diagnostic procedure. Int Psychogeriatr. Suppl 1. 1997;9:123-130. [pmid: 9447435].
Starkstein SE, Sabe L, Vazquez S, et al. Neuropsychological, psychiatric, and cerebral perfusion correlates of leukoaraiosis in Alzheimer's disease. J Neurol Neurosurg Psychiatry. 1997;63(1):66-73. [pmid: 9221970].
Starkstein SE, Sabe L, Vazquez S, et al. Neuropsychological, psychiatric, and cerebral blood flow findings in vascular dementia and Alzheimer's disease. Stroke. 1996;27(3):408-414. [pmid: 8610304].
Stoppe G, Staedt J, Kogler A, et al. 99mTc-HMPAO-SPECT in the diagnosis of senile dementia of Alzheimer's type--a study under clinical routine conditions. J Neural Transm Gen Sect. 1995;99(1–3):195-211. [pmid: 8579805].
Sunderland T, Esposito G, Molchan SE, et al. Differential cholinergic regulation in Alzheimer's patients compared to controls following chronic blockade with scopolamine: a SPECT study. Psychopharmacology (Berl). 1995;121(2):231-241. [pmid: 8545529].
Szelies B, Mielke R, Herholz K, et al. Quantitative topographical EEG compared to FDG PET for classification of vascular and degenerative dementia. Electroencephalogr Clin Neurophysiol. 1994;91(2):131-139. [pmid: 7519142].
Talbot PR, Lloyd JJ, Snowden JS, et al. A clinical role for 99mTc-HMPAO SPECT in the investigation of dementia. J Neurol Neurosurg Psychiatry. 1998;64(3):306-313. [pmid: 9527139].
Talbot PR, Snowden JS, Lloyd JJ, et al. The contribution of single photon emission tomography to the clinical differentiation of degenerative cortical brain disorders. J Neurol. 1995;242(9):579-586. [pmid: 8551319].
Tanna NK, Kohn MI, Horwich DN, et al. Analysis of brain and cerebrospinal fluid volumes with MR imaging: impact on PET data correction for atrophy. Part II. Aging and Alzheimer dementia. Radiology. 1991;178(1):123-130. [pmid: 1984290].
Terry RD, Katzman R. Senile dementia of the Alzheimer type. Ann Neurol. 1983;14(5):497-506. [pmid: 6139975].
Tikofsky RS, Harsch HH, Goldstein MD, et al. CT, magnetic resonance imaging, and SPECT iodine-123 iodoamphetamine imaging of a patient with progressive cognitive deterioration. Clin Nucl Med. 1987;12(6):463-465. [pmid: 3496185].
Tohgi H, Yonezawa H, Takahashi S, et al. Cerebral blood flow and oxygen metabolism in senile dementia of Alzheimer's type and vascular dementia with deep white matter changes. Neuroradiology. 1998;40(3):131-137. [pmid: 9561514].
Tyrrell PJ, Rossor MN. Extrapyramidal signs in dementia of Alzheimer type. Lancet. 1989;2(8668):920. [pmid: 2571838].
Vallabhajosula S, Buchsbaum M. PET studies in psychiatry: validity, accuracy and future. J Nucl Med. 1994;35(1):24-26. [pmid: 8271055].
van Dyck CH, Gelernter J, MacAvoy MG, et al. Absence of an apolipoprotein E epsilon4 allele is associated with increased parietal regional cerebral blood flow asymmetry in Alzheimer disease. Arch Neurol. 1998;55(11):1460-1466. [pmid: 9823831].
van Dyck CH, Lin CH, Smith EO, et al. Comparison of technetium-99m-HMPAO and technetium-99m-ECD cerebral SPECT images in Alzheimer's disease. J Nucl Med. 1996;37(11):1749-1755. [pmid: 8917168].
van Gool WA. The use of apolipoprotein E genotyping as a diagnostic test in suspected Alzheimer's disease. Ann N Y Acad Sci. 1996;802:79-91. [pmid: 8993487].
Van Gool WA, Walstra GJ, Teunisse S, et al. Diagnosing Alzheimer's disease in elderly, mildly demented patients: the impact of routine single photon emission computed tomography. J Neurol. 1995;242(6):401-405. [pmid: 7561970].
Vander Borght T, Minoshima S, Giordani B, et al. Cerebral metabolic differences in Parkinson's and Alzheimer's diseases matched for dementia severity. J Nucl Med. 1997;38(5):797-802. [pmid: 9170449].
Varma AR, Talbot PR, Snowden JS, et al. A 99mTc-HMPAO single-photon emission computed tomography study of Lewy body disease. J Neurol. 1997;244(6):349-359. [pmid: 9249619].
Velakoulis D, Lloyd JH. The role of SPECT scanning in a neuropsychiatry unit. Aust N Z J Psychiatry. 1998;32(4):511-522. [pmid: 9711365].
Venneri A, Shanks MF, Staff RT, et al. Nurturing syndrome: a form of pathological bereavement with delusions in Alzheimer's disease. Neuropsychologia. 2000;38(2):213-224. [pmid: 10660231].
Villa G, Cappa A, Tavolozza M, et al. Neuropsychological tests and [99mTc]-HM PAO SPECT in the diagnosis of Alzheimer's dementia. J Neurol. 1995;242(6):359-366. [pmid: 7561963].
Vines DC, Ivo BD, Ballinger JR, et al. External radioactive reference markers in SPECT imaging of the dopamine system. J Nucl Med Technol. 1999;27(2):112-116. [pmid: 10353107].
Wada H. Analyses of serum concentrations of apolipoproteins in the demented elderly. Intern Med. 2000;39(3):220-222. [pmid: 10772123].
Waldemar G, Christiansen P, Larsson HB, et al. White matter magnetic resonance hyperintensities in dementia of the Alzheimer type: morphological and regional cerebral blood flow correlates. J Neurol Neurosurg Psychiatry. 1994;57(12):1458-1465. [pmid: 7798973].
Waldemar G, Hogh P, Paulson OB. Functional brain imaging with single-photon emission computed tomography in the diagnosis of Alzheimer's disease. Int Psychogeriatr. Suppl 1. 1997;9:223-227. [pmid: 9447443].
Walker Z, Costa DC, Ince P, et al. In-vivo demonstration of dopaminergic degeneration in dementia with Lewy bodies. Lancet. 1999;354(9179):646-647. [pmid: 10466669].
Walker Z, Costa DC, Janssen AG, et al. Dementia with lewy bodies: a study of postsynaptic dopaminergic receptors with iodine-123 iodobenzamide single-photon emission tomography. Eur J Nucl Med. 1997;24(6):609-614. [pmid: 9169566].
Walstra GJ, Teunisse S, van Gool WA, et al. Reversible dementia in elderly patients referred to a memory clinic. J Neurol. 1997;244(1):17-22. [pmid: 9007740].
Weinstein HC, Hijdra A, van Royen EA, et al. Determination of cerebral blood flow by SPECT: a valuable tool in the investigation of dementia. Clin Neurol Neurosurg. 1989;91(1):13-19. [pmid: 2538276].
Weinstein HC, Scheltens P, Hijdra A, et al. Neuro-imaging in the diagnosis of Alzheimer's disease. II. Positron and single photon emission tomography. Clin Neurol Neurosurg. 1993;95(2):81-91. [pmid: 8344019].
Wolf H, Grunwald M, Ecke GM, et al. The prognosis of mild cognitive impairment in the elderly. J Neural Transm. Suppl. 1998;54:31-50.
Wolf-Klein GP. Symptoms, diagnosis, and management of Alzheimer's disease. Compr Ther. 1990;16(9):25-29. [pmid: 2122939].
Wragg RE, Jeste DV. Overview of depression and psychosis in Alzheimer's disease. Am J Psychiatry. 1989;146(5):577-587. [pmid: 2653053].
Wszolek ZK, Herkes GK, Lagerlund TD, et al. Comparison of EEG background frequency analysis, psychologic test scores, short test of mental status, and quantitative SPECT in dementia. J Geriatr Psychiatry Neurol. 1992;5(1):22-30. [pmid: 1571070].
Yasuno F, Imamura T, Hirono N, et al. Age at onset and regional cerebral glucose metabolism in Alzheimer's disease. Dement Geriatr Cogn Disord. 1998;9(2):63-67. [pmid: 9524795].
Yoshida T, Kuwabara Y, Ichiya Y, et al. Cerebral muscarinic acetylcholinergic receptor measurement in Alzheimer's disease patients on 11C-N-methyl-4-piperidyl benzilate-comparison with cerebral blood flow and cerebral glucose metabolism. Ann Nucl Med. 1998;12(1):35-42. [pmid: 9559960].
Zakzanis KK. Quantitative evidence for neuroanatomic and neuropsychological markers in dementia of the Alzheimer's type. J Clin Exp Neuropsychol. 1998;20(2):259-269. [pmid: 9777480].
Zimmer R, Leucht S, Radler T, et al. Variability of cerebral blood flow deficits in 99mTcHMPAO SPECT in patients with Alzheimer's disease. J Neural Transm. 1997;104(67):689-701. [pmid: 9444568].