# References

Adams E, Flynn K. Positron emission tomography: A systematic review update of FDGPET as a diagnostic test in cancer and Alzheimer's disease. Technology Assessment Report No 10. Health Services Research and Development Service, Department of Veterans Affairs. 1998.
Azari NP, Pettigrew KD, Schapiro MB, et al. Early detection of Alzheimer's disease: a statistical approach using positron emission tomographic data. J Cereb Blood Flow Metab. 1993;13(3):438-447. [pmid: 8478402].
Birks J, Flicker L. Selegiline for Alzheimer's disease (Cochrane Review). The Cochrane Library, Issue 3, 2001. Oxford. Update Software.
Bookheimer SY, Strojwas MH, Cohen MS, et al. Patterns of brain activation in people at risk for Alzheimer's disease. N Engl J Med. 2000;343(7):450-456. [pmid: 10944562].
Bowen J, Teri L, Kukull W, et al. Progression to dementia in patients with isolated memory loss. Lancet. 1997;349(9054):763-765. [pmid: 9074575].
Brookmeyer R, Gray S, Kawas C. Projections of Alzheimer's disease in the United States and the public health impact of delaying disease onset. Am J Publ Health. 1998;88(9):1337-1342.
Burdette JH, Minoshima S, Vander Borght T, et al. Alzheimer disease: improved visual interpretation of PET images by using three-dimensional stereotaxic surface projections. Radiology. 1996;198(3):837-843. [pmid: 8628880].
Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease - results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237-244. [pmid: 10325453].
Clark CM, Trojanowski JQ. Neurodegenerative dementias. New York. McGraw-Hill. 2000.
Doody RS, Stevens JC, Beck C, et al. Practice parameter: management of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1154-1166. [pmid: 11342679].
Doraiswamy PM, Steffens DC, Pitchumoni S, et al. Early recognition of Alzheimer's disease: what is consensual? What is controversial? What is practical?. J Clin Psychiatry. Suppl 13. 1998;59:6-18. [pmid: 9771825].
Drickamer MA, Lachs MS. Should patients with Alzheimer's disease be told their diagnosis?. N Engl J Med. 1992;326(14):947-951. [pmid: 1542346].
Duara R, Barker W, Loewenstein D, et al. Sensitivity and specificity of positron emission tomography and magnetic resonance imaging studies in Alzheimer's disease and multi-infarct dementia. Eur Neurol. Suppl 3. 1989;29:9-15. [pmid: 2612532].
Erde EL, Nadal EC, Scholl TO. On truth telling and the diagnosis of Alzheimer's disease. J Family Pract. 1988;26(4):401-406.
Fazekas F, Alavi A, Chawluk JB, et al. Comparison of CT, MR, and PET in Alzheimer's dementia and normal aging. J Nucl Med. 1989;30(10):1607-1615. [pmid: 2795200].
Getsios D, Caro JJ, Caro G, et al. Assessment of health economics in Alzheimer's disease (AHEAD): galantamine treatment in Canada. Neurology. 2001;57(6):972-978. [pmid: 11571319].
Grady CL, Haxby JV, Schapiro MB, et al. Subgroups in dementia of the Alzheimer type identified using positron emission tomography. J Neuropsychiatry Clin Neurosci. 1990;2(4):373-384. [pmid: 2136389].
Gurwitz D. Immunization for Alzheimer's disease: yet closer to clinical trials. Trends Molec Med. 2001;7(9):385. [pmid: 11530319].
Herholz K. Criteria for the diagnosis of Alzheimer's disease with Positron Emission Tomography. Dementia. 1990;(1):156-164.
Herholz K, Perani D, Salmon E, et al. Comparability of FDG PET studies in probable Alzheimer's disease. J Nucl Med. 1993;34(9):1460-1466. [pmid: 8355064].
Higuchi M, Tashiro M, Arai H, et al. Glucose hypometabolism and neuropathological correlates in brains of dementia with Lewy bodies. Exp Neurol. 2000;162(2):247-256. [pmid: 10739631].
Hoffman JM, Welsh-Bohmer KA, Hanson M, et al. FDG PET imaging in patients with pathologically verified dementia. J Nucl Med. 2000;41(11):1920-1928. [pmid: 11079505].
Holroyd S, Snustad DG, Chalifoux ZL. Attitudes of older adults' on being told the diagnosis of Alzheimer's disease. J Am Geriatr Soc. 1996;44(4):400-403. [pmid: 8636584].
Irwig L, Macaskill P, Glasziou P, et al. Meta-analytic methods for diagnostic test accuracy. J Clin Epidemiol. 1995;48(1):119-130. [pmid: 7853038].
Ishii K, Imamura T, Sasaki M, et al. Regional cerebral glucose metabolism in dementia with Lewy bodies and Alzheimer's disease. Neurology. 1998;51(1):125-130. [pmid: 9674790].
Katzman R. Iqbal K, Sisodia S, Winbald B, editors. Alzheimer's disease: Epidemiology of Alzheimer's disease and dementia: advances and challenges. Advances in etiology, pathogenesis and therapeutics. New York. John Wiley and Sons, Ltd. 2001.
Kippenhan JS, Barker WW, Pascal S, et al. Evaluation of a neural-network classifier for PET scans of normal and Alzheimer's disease subjects. J Nucl Med. 1992;33(8):1459-1467. [pmid: 1634935].
Knopman DS, DeKosky ST, Cummings JL, et al. Practice parameter: diagnosis of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1143-1153. [pmid: 11342678].
Larson EB, Kukull WA, Katzman RL. Cognitive impairment: dementia and Alzheimer's disease. Annual Rev Publ Health. 1992;13:431-449.
Lau J, Ioannidis JPA, Balk E, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments. Evidence Report/Technology Assessment No 26. Available at Agency for Healthcare Research and Quality website. Available at http://www.ahrq.gov. Accessed December 6, 2001.
Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in careers of patients with Alzheimer's disease. Br J Psychiatry. 2000;176:557-562. [pmid: 10974962].
McKhann G, Drachman D, Folstein M, et al. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34(7):939-944. [pmid: 6610841].
Messa C, Perani D, Lucignani G, et al. High-resolution technetium-99m-HMPAO SPECT in patients with probable Alzheimer's disease: comparison with fluorine-18-FDG PET. J Nucl Med. 1994;35(2):210-216. [pmid: 8294987].
Mielke R, Pietrzyk U, Jacobs A, et al. HMPAO SPET and FDG PET in Alzheimer's disease and vascular dementia: comparison of perfusion and metabolic pattern. Eur J Nucl Med. 1994;21(10):1052-1060. [pmid: 7828614].
Minoshima S, Frey KA, Foster NL, et al. Preserved pontine glucose metabolism in Alzheimer disease: a reference region for functional brain image (PET) analysis. J Comput Assist Tomogr. 1995;19(4):541-547. [pmid: 7622680].
Mittelman MS, Ferris SH, Shulman E, et al. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. 1996;276(21):1725-1731. [pmid: 8940320].
Mohs RC, Breitner JC, Silverman JM, et al. Alzheimer's disease. Morbid risk among first-degree relatives approximates 50% by 90 years of age. Arch Gen Psychiatry. 1987;44(5):405-408. [pmid: 3579492].
Mohs RC, Doody RS, Morris JC, et al. A 1-year, placebo-controlled preservation of function survival study of donepezil in Alzheimer's disease patients. Neurology. 2001;57(1):481-488. [pmid: 11502917].
Morris JC, McKeel DW Jr, Storandt M, et al. Very mild Alzheimer's disease: informant-based clinical, psychometric, and pathologic distinction from normal aging. Neurology. 1991;41(4):469-478. [pmid: 2011242].
Morris JC, Storandt M, Miller JP, et al. Mild cognitive impairment represents early-stage Alzheimer disease. Arch Neurol. 2001;58(3):397-405. [pmid: 11255443].
Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293-1316. [pmid: 8210827].
Neumann PJ, Kuntz KM, Leon J, et al. Health utilities in Alzheimer's disease: a cross-sectional study of patients and caregivers. Med Care. 1999;37(1):27-32. [pmid: 10413389].
Ohyama M, Senda M, Mishina M, et al. Semi-automatic ROI placement system for analysis of brain PET images based on elastic model: application to diagnosis of Alzheimer's disease. Keio J Med. Suppl 1. 2000;49:A105-A106. [pmid: 10750353].
Petersen RC, Stevens JC, Ganguli M, et al. Practice parameter: early detection of dementia: mild cognitive impairment (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1133-1142. [pmid: 11342677].
Powers WJ, Perlmutter JS, Videen TO, et al. Blinded clinical evaluation of positron emission tomography for diagnosis of probable Alzheimer's disease. Neurology. 1992;42(4):765-770. [pmid: 1565229].
Roses AD. Apolipoprotein E, a gene with complex biological interactions in the aging brain. Neurobiol Dis. 1997;4(3–4):170-185. [pmid: 9361294].
Rubensztein DC, Easton DF. Apolipoprotein E genetic variation and Alzheimer's disease: a meta-analysis. Dement Geriatr Cogn Disord. 1999;10:199-209. [pmid: 10325447].
Salmon E, Sadzot B, Maquet P, et al. Differential diagnosis of Alzheimer's disease with PET. J Nucl Med. 1994;35(3):391-398. [pmid: 8113882].
Scinto L, Daffner K. Early diagnosis of Alzheimer's disease. Tottowa, NJ. Humana Press. 2000.
Selkoe DJ. The cell biology of beta-amyloid precursor protein and presenilin in Alzheimer's disease. Trends Cell Biol. 1998;11:447-453. [pmid: 9854312].
Sigurdsson EM, Scholtzova H, Mehta PD, et al. Immunization with a nontoxic/nonfibrillar amyloid-beta homologous peptide reduces Alzheimer's disease-associated pathology in transgenic mice. Am J Pathol. 2001;159(2):439-447. [pmid: 11485902].
Silverman DH, Small GW, Chang CY, et al. Positron emission tomography in evaluation of dementia. JAMA. 2001;286(17):2120-2127. [pmid: 11694153].
Small GW, Ercoli LM, Silverman DH, et al. Cerebral metabolic and cognitive decline in persons at genetic risk for Alzheimer's disease. Proc Natl Acad Sci U S A. 2000;97(11):6037-6042. [pmid: 10811879].
Szelies B, Mielke R, Herholz K, et al. Quantitative topographical EEG compared to FDG PET for classification of vascular and degenerative dementia. Electroencephalogr Clin Neurophysiol. 1994;91(2):131-139. [pmid: 7519142].
Walstra GJ, Teunisse S, van Gool WA, et al. Reversible dementia in elderly patients referred to a memory clinic. J Neurol. 1997;244(1):17-22. [pmid: 9007740].