# Results

Through grey literature searches, we identified 15 new genetic tests (targeting 17 diseases) for non-cancer conditions available since our 2010 horizon scan report on Genetic Testing for Non-Cancer Conditions. These tests are used to assess non-cancer disease risk associations (13 tests assessing a panel of genes) and pharmacogenomic applications (2 tests). Concise summaries of relevant information concerning these tests are compiled in our internal genetic test database (see Appendix A).

We also confirmed that all 90 genetic tests (101 test-disease combinations) that were listed in our 2007 report remain available for clinical use. In addition, a search of the FDA Web site indicated that only five (targeting three disease conditions) of the 90 tests have been cleared by the FDA. These include: the factor V and MTHFR genetic tests for thrombophilia, UGT1A1 for Crigler-Najjar syndrome and Gilbert syndrome, and a panel of 11 genes in XDx Allomap Molecular Expression testing for acute cellular organ transplant rejection. These are listed in Appendix B, Table 1. For additional information on genetic tests cleared by the FDA, readers of this report should refer to the FDA Web site. The list of pharmacogenomic biomarkers in drug labels posted at the FDA Web site is included in Appendix C, Table 1.