# Objectives

The main objective of this report is to provide a broad but succinct overview of each identified genetic test, and to provide a preliminary estimate of the amount of published literature currently available for each genetic test. The report and the accompanying database serve as a ready reference for decisions on generating future topics for systematic reviews. The contents of the database reflect data obtained from manufacturers’ Web sites or other Internet sources and should not be construed as definitive clinical evidence. This report is not meant to serve as an in-depth or systematic review. A systematic evaluation of the topic or of selected tests is left to future reviews.