# Methods

We adopted the 2007 and 2010 horizon scan report on Genetic Testing for Non-Cancer Conditions as a model for this report.4,5 We adopted all the terminologies used in the previous report. As part of this project, we also developed an internal database to collect information on genetic tests. The current report represents the updated state of this database of genetic tests for non-cancer conditions and provides concise summaries for all newly identified tests since 2010. For readers’ convenience, some sections from the 2010 horizon scan report on Genetic Testing for Non-Cancer are reproduced in this section.

## Terminologies, Definitions, and Eligibility Criteria

### Genetic Test Definition

We adopted the National Institutes of Health (NIH) working definition for genetic tests drawn from the 2008 Report of the Secretary’s Advisory Committee on Genetics, Health, and Society (http://oba.od.nih.gov). (Please note that this definition may change as technologies continue to evolve.)

“A test that involves an analysis of human chromosomes, deoxyribonucleic acid, ribonucleic acid, genes and/or gene products (e.g., enzymes, other types of proteins, and selected metabolites), which is predominantly used to detect heritable or somatic mutations, genotypes, or chromosomal variations in structure or number related to disease, health, and/or personalized medicine.”

### Eligibility Criteria

#### Inclusion Criteria

We included genetic tests already in use in clinical practice and would impact the health outcomes of the population of interest (adults in the Medicare age group). We included genetic conditions that could manifest in adulthood, such as Huntington’s disease (a degenerative brain condition). We also included genetic tests for diseases/conditions whose symptoms may be recognized until adulthood, even though the onset may have begun at an early age (e.g., Marfan syndrome, a connective tissue disorder). We included tests that aided in the diagnosis, treatment, prediction, and prognosis of non-cancer disease conditions in adult patients of the Medicare age group, and which met the following criteria:

1. Cleared by the U.S. Food and Drug Administration (FDA), or
2. Conducted in Clinical Laboratory Improvement Amendments (CLIA) certified labs and requiring a physician order, or
3. Conducted by an Internet-based genetic testing service and requiring a physician order.

#### Exclusion Criteria

We excluded tests performed for the purpose of identifying carrier status of heritable diseases, prenatal diagnosis, and conditions that affect only newborns and children that result in early deaths (e.g., Canavan disease, a degenerative brain disease). We excluded tests targeted for cancer conditions. These tests will be considered in a subsequent report. We excluded tests that are still in research development.

## Clinical Applications of Genetic Tests

For the clinical applications of genetic tests that are covered in this report, we mostly adopted the terminologies used in the previous horizon scan reports on Genetic Testing for Non-Cancer Conditions. The following categories were used to describe the different applications for the various eligible genetic tests:

1. Prevention: To detect inherited susceptibility to adult-onset non-cancer conditions in persons who do not have the disease in order to initiate appropriate interventions.
2. Diagnosis and management: Includes confirming, classifying, and predicting the typical course of a disease; choosing type of treatment (e.g., lifestyle modifications or medical therapy); monitoring response to therapy; and predicting outcomes (predictive tests).

Tests that were categorized as aiding in diagnosis and management were further classified into diagnostic, prognostic, and monitoring.

1. Diagnostic: Test used to confirm or aid in the diagnosis of the particular disease.
2. Prognostic: Information from the test can be used to determine or predict the aggressiveness of the disease or overall outcome of the disease, at the time of initial diagnosis and prior to initiation of treatment. Prognostic information can then be used to determine a particular or individualized treatment plan.
3. Predictive: Information from the test can be used to determine or predict overall outcome of the disease with treatment.
4. Monitoring: Test used to monitor tumor and/or patient response to treatment.

## Searches

We conducted focused searches of grey literature sources, including online genetic databases, registries, and laboratories, to identify new genetic tests that are currently in clinical use. One definition of grey literature is, “that which is produced on all levels of government, academics, business and industry in print and electronic formats, but which is not controlled by commercial publishers”.6 Listed below are Web sites that were frequently visited to gather information on new genetic tests.

### Description of Grey Literature Sources

1. Genetic Testing Registry: Genetic Testing Registry (http://www.ncbi.nlm.nih.gov/gtr) is a Web site funded by the National Institutes of Health (NIH), with an overarching goal to advance public health and research into the genetic basis of health and disease. The NIH Genetic Testing Registry (NIH GTR) has been available since February 2012 as a central location for genetic test information submitted voluntarily by providers. The current scope includes the purpose, methodology, validity, and evidence of usefulness of the tests, as well as laboratory contacts and credentials. This Web site also includes materials that were previously available at the GeneTests.org.
2. GeneTests: GeneTests (http://www.genetests.org) is a Web site funded by the NIH and sponsored by the University of Washington in Seattle. The current Web site includes links to the International Laboratory Directory, the International Genetics Clinic Directory, GeneReviews, and Educational Materials. The purpose of this Web site is to provide medical genetics information to physicians, other healthcare providers, and researchers. GeneTests.org is available free of charge to all interested persons. GeneReviews is authored and reviewed by experts in the field of genetics, updated and/or revised periodically as clinically relevant material emerges. GeneReviews allows searches to be conducted by disease name, gene symbol, chromosomal locus, protein name, feature, Online Mendelian Inheritance in Man (OMIM) number, author, or title. The GeneTests.org reports that the International Laboratory Directory is a voluntary listing of laboratories offering molecular genetic testing, specialized cytogenetic testing, and biochemical testing for inherited disorders. We obtained information related to testing, clinical uses, and other resources from the GeneReviews section of the GeneTests.org Web site. We also utilized the links to commercial diagnostic laboratories that were provided by testing sources to explore the specimen collection methods, methodology, and genetic disease/condition descriptions.
3. Google News: We searched Google News (http://www.news.google.com) using the following search terms: (“gene OR genetic OR genomic test OR epigenetic OR proteomic”) AND (“FDA cleared OR clearance”). The news items and their links were automatically deposited into an email system to give daily email alerts. The alerts were screened periodically (weekly or biweekly basis). We visited Web links listed in the news items. We also visited Web sites for relevant laboratories that appeared in the news items to identify any new genetic tests.
4. Commercial diagnostic laboratories: These laboratory Web sites were screened to identify genetic tests that are available for routine clinical use. We also identified the Web sites of companies or major commercial laboratories in the US, such as Roche Diagnostics^®^, Quest Diagnostics^®^, LabCorp^®^, and Arup Laboratories. A complete list of systematically queried laboratories and their Web sites can be found in Table 1. For any potential genetic tests that were mentioned in these Web sites, we conducted focused Internet searches by including the specific test names to find more information, including other manufacturers, suggested uses, and press releases.
5. Other Internet sites: At the direction of experts in the field of genetics, we searched for news tests available at the following Web sites: PHG Foundation (phgfoundation.org) and EGAPP Reviews (egappreviews.org).
6. The Office of In Vitro Diagnostics Device Evaluation and Safety (OIVD): OIVD (http://www.fda.gov/cdrh/oivd/consumer-otcdatabase.html) is part of the FDA Center for Devices and Radiological Health. The OIVD regulates all aspects of in-home and laboratory diagnostic tests (in vitro diagnostic devices, or IVDs), helps new IVDs reach the medical marketplace, prevents the sale of unsafe or ineffective IVDs, and categorizes the complexity of IVDs according to the Clinical Laboratory Improvement Amendments of 1988 (CLIA '88), which defines the type of regulatory oversight applied. The OIVD Web site (http://www.fda.gov/cdrh/oivd) was explored to identify genetic tests currently cleared by the FDA. The search of this Web site for approved genetic tests requires unique product-specific queries. Further explorations of the Genomics Web site at the FDA were also conducted.
7. FDA Pre-market Approval: We searched the FDA’s online pre-market approval database (http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMA/pma.cfm). The Medical Device Amendments of 1976 to the Federal Food, Drug, and Cosmetic Act established three regulatory classes for medical devices. The amendments define a Class III device as “one that supports or sustains human life or is of substantial importance in preventing impairment of human health or presents a potential, unreasonable risk of illness or injury.” All devices placed into Class III are subject to pre-market approval requirements. Pre-market approval by the FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices.
8. PharmGKB: PharmGKB (www.pharmgkb.org) is a Web site maintained by Stanford University. The two currently developing fields of pharmacogenetics (focuses on single genes) and pharmacogenomics (focuses on multiple genes) were identified as possibly providing insights into the inter-individual variability of drug responses. As such, we also culled genetic tests from the PharmGKB (www.pharmgkb.org) Web site.
9. American Medical Association’s (AMA) Current Procedural Terminology (CPT) Editorial Panel 2012: We reviewed the list of genetic tests available in the AMA CPT Editorial Panel 2012 and examined those against the tests that were previously available in our genetic test database.
10. GAPP Finder: GAPP Finder
  (http://www.hugenavigator.net/GAPPKB/topicStartPage.do) is an online resource of a searchable knowledge base of genomic applications in practice and prevention. The GAPP Finder is supported by Center for Disease Control Office of Public Health Genomics.

## Updating the Database

Horizon scanning has been ongoing since 2007 by the Tufts EPC, and our internal database is continuously updated as genetic tests are identified. The results of grey literature searches, along with concise summaries of each identified test, are added to this database monthly.

## Tracking the Evolution

We conducted grey literature searches in March 2012 to identify whether the 90 genetic tests (targeting 101 different diseases, herein referred as test-disease combination) identified in our 2007 report remained available. In addition, we searched the FDA Web site to identify whether these tests have been cleared by the FDA.

Table 1 Web sites that were investigated to identify new genetic tests for non-cancer conditions

Description | URL
Quest Diagnostics^®^ | http://www.questdiagnostics.com
LabCorp^®^ | http://www.labcorp.com
Roche Diagnostics^®^ | http://www.roche-diagnostics.us
Athena Diagnostics, Inc. | http://www.athenadiagnostics.com
GeneDx | http://www.genedx.com
Google News | http://news.google.com
FDA News | http://FDAnews.com
Genetic Testing Registry | http://www.ncbi.nlm.nih.gov/gtr
GeneTests | http://www.ncbi.nlm.nih.gov/sites/GeneTests/?db=GeneTests
Ambry Genetics | http://www.ambrygen.com
Harvard Medical School Lab for Molecular Medicine | http://www.hpcgg.org
Mayo Clinic Medical Labs | www.mayomedicallaboratories.com
NeuroMark | www.neuromark.com
Kimballgenetics | www.kimballgenetics.com
Ilgenetics | www.ilgenetics.com
Genelex | http://www.healthanddna.com
Epigenomics | http://www.epigenomics.com
Correlogic | http://www.correlogic.com
DeCODE | http://www.decode.com

## Individual Test Summaries

Once the list of current genetic tests was updated, a series of concise summaries of each test in the database was compiled using data extracted from various sources, including manufacturers’ and other publically available Web sites. Included in these summaries was a more detailed description of the test and its clinical use. Each summary included the following items:

- Test name: The majority of the clinically available genetic tests were identified either by the disease/conditions or by the disease-causing genes, without any specific test name. Hence, gene names, protein, and disease/conditions often served as surrogate identifiers for genetic tests. When available, we recorded the specific test name. •
- Test description: A brief summary of a genetic or genomic test and its association with the non-cancer condition.
- Purpose: The clinical applications of genetic tests include primary or secondary prevention, diagnostic, prognostic, recurrence, and monitoring.
- Availability: A brief list of laboratories, including commercial and academic laboratories in the US and other countries.
- Specimen: The specimen (e.g., whole blood, buccal swab, etc.) that was utilized to evaluate gene-disease condition.
- Diseases: A list of disease conditions for which a genetic test was utilized (e.g., dilated cardiomyopathy, psoriatic arthritis, etc.).
- Clinical uses: Applications in a clinical setting (e.g., routine use, investigational use, etc.).
- Source: A list of additional sources that was typically consulted for information about a genetic test application.
- Exploratory PubMed® search: The exploratory PubMed search included the name of a genetic or molecular marker, the disease, and the terms “non-cancer condition [mh]” (e.g., dilated cardiomyopathy) and “humans [mh]” connected with the Boolean operator “AND.” For tests that use a panel of genetic or molecular markers, we used the brand name of the panel crossed with the search terms. All searches were repeated on 3/1/2012. These search strategies were exploratory, and the number of citations returned was used as a rough estimate of the volume of scientific literature available on each test-disease condition.
- FDA cleared: Indicating whether a genetic test has been cleared by the FDA for clinical use.

## Description of the Electronic Database

We developed an in-house electronic database that resides within Tufts EPC for the efficient storage and retrieval of the previously described summary information on eligible genetic tests. For convenience, we developed a user-friendly interface that allows for browsing and searching of the database without the need for programming.

### MySQL Database

We have created a MySQL (http://www.mysql.com) database to store the collected genetic test information. In this genetic test database, data are separated into cancer and non-cancer genetic tests. We keep a record of all the data needed to generate the summaries for each genetic test.

### Front End

While our internal MySQL database stores and indexes genetic tests, accessing the data is not necessarily straightforward for those unfamiliar with MySQL (and the SQL query language). To make the database more widely accessible, we have developed a user-friendly interface through which to access the database, dubbed the “GeneTestTracker.” The front end is Web-based and written in the Python programming language (http://python.org), using the Pylons (http://pylonshq.com) Web framework. Having a Web-based program is advantageous because it allows for remote access (via any standard Internet browser), is platform independent, and can be easily updated without requiring users to reinstall software.

Upon logging into the password-protected site, users can see genetic tests in a tabular format; the non-cancer tests are displayed on one tabbed page (Figure 1). From this screen, users can add a new genetic test by simply clicking the “Add new” button. Furthermore, users can click on an existing gene test to bring up the corresponding one-page summary. This summary can then be edited or deleted by the user. Additionally, a Microsoft© Word-friendly Rich Text Format (RTF) document can be automatically generated from the summary page, which the user can print out or download to their computer locally. After including appropriate search terms, the database interfaces with PubMed so as to automatically generate the number of citations a search in PubMed turns up for a specific gene test.

Figure 1 The front end to GeneTestTracker, the electronic database that lists genetic and genomic tests

Figure 1 (page 14) is a snapshot of Gene Test Tracker, the front end to the electronic database that lists genetic and genomic tests. After logging in the password-protected site, the user sees an html page depicting a table. Each row pertains to a specific test. The columns list the test name, gene symbol, protein name, test name, non-cancer condition and description of disease, purpose of the test, availability, specimen, methodology, clinical use, sources, marker, organ, PubMed search strategies, the number of PubMed hits, the date of update, and FDA approval status for the test. Above the columns is a search window where the user may search the database for any genetic test within two categories, cancer and non-cancer. The database may be searched using the test name, gene symbol, disease, or laboratory as keywords to find a specific test or any number of tests currently available for a specific disease.

After logging into the password-protected site, the user sees an HTML page depicting a table. Each row pertains to a specific genetic test. The columns list the test name, gene symbol, protein name, test name, non-cancer condition and description of disease, purpose of the test, availability, specimen, methodology, clinical use, sources, marker, organ, PubMed search strategies, the number of PubMed hits, the date of update, and the FDA approval status for the test. Above the columns is a search window where the user may search the database for any genetic test within two categories, cancer and non-cancer. The database may be searched using the test name, gene symbol, disease, or laboratory as keywords to find a specific test or any number of tests currently available for a specific disease. The database is currently available for internal use only.