# Discussion

Genetic testing is a rapidly emerging field with the potential to dramatically influence clinical decisionmaking. Most of the information for each of the tests we identified was gathered from various public and proprietary Web sites. Laboratories offering genetic testing services provided most of the information on the description of the specific gene(s) involved with a particular disease. The Web sites we used were mostly identified in our previous horizon scan reports on Genetic Testing for Non-Cancer Conditions. Our list encompasses both gene associations of potential biomarkers that are available in clinical use and tests that predict response to clinical use. Our report indicates that there has been an increase in the number of genetic tests for specific non-cancer conditions (e.g., cardiovascular diseases). Compared with earlier reports, recent grey literature searches indicate that many genetic tests are currently being marketed as multi-panel tests (panel of multiple gene evaluations).

A number of efforts to catalogue information on genetic tests have been undertaken by varying national agencies. These online resources provide genetic test information to keep stakeholders abreast of available tests. While all these databases gather information on genetic tests, their methodologies are quite different. The earliest online resource was GeneTests.org, funded by the NIH and sponsored by the University of Washington in Seattle gathers information volunteered by testing providers. More recently, though still nascent, the NIH GTR, which relies solely on information volunteered by testing providers, came online since February 2012.^7^ Another, the GAPP Finder, supported by the Center for Disease Control Office of Public Health Genomics, gathers information on genomic tests through systematic surveillance of the Internet.8 For all these databases, the data gathered can include information on both tests in development and in clinical use.

Because research into genetics progresses rapidly, the logistics of identifying a comprehensive list of genetic tests poses a significant challenge. Our database includes genetic tests identified through active searches conducted in grey literature sources. The present report is valuable as an up-to-date listing and description of genetic tests in current clinical use with a specific applicability to older adults. Although our database is not publicly available (efforts are currently ongoing to make it freely accessible), its contents are updated monthly, peer-reviewed, and then published as reports, biennially. Furthermore, we have used our electronic database for critical evaluation of genetic tests using evidence-based methodology.9–11

Potential limitations of this report include the lack of an empirical structure providing guidance on how to conduct optimal grey literature searches of the Internet. For example, searches using modern search engines such as Google are not strictly reproducible. This has been partially overcome by storing Web addresses along with access dates in our database. Another limitation stems from our reliance on Internet searching without further contact with the manufacturers of genetic tests. Currently, this process limits our ability to identify a test with multiple commercial names (for example, a test that has been licensed from one company to another company but carries a different commercial name for the same test) or to identify if changes were made to a test but the name remains unchanged (for example, when additional single-nucleotide polymorphisms are added to a test).

In summary, the current report is a valuable source of genetic tests in current clinical use with specific applicability to older adults. However, we believe that further efforts should be undertaken to integrate different online databases funded through various agencies into one comprehensive registry of genomic tests. In addition, further empirical research is needed to assess the optimal evidence sources for identifying newly clinically available genetic tests. Progress in translational research will be made only if new products or technologies are used in clinical practice, which requires education and awareness. Health care providers, patients, payers, decision-makers, and consumers can all benefit from staying abreast of the rapidly expanding field of genetic testing.