# Pharmacogenomic Biomarkers in Drug Labels from the FDA Web site

Table 1 Pharmacogenomic Biomarkers in Drug Labels from the FDA Web site

Drug | Therapeutic area | Biomarker
Desloratadine and Pseudoephedrine | Allergy | CYP2D6
Celecoxib | Analgesics | CYP2C9
Codeine | Analgesics | CYP2D6
Tramadol and Acetaminophen | Analgesics | CYP2D6
Quinidine | Antiarrhythmics | CYP2D6
Terbinafine | Antifungals | CYP2D6
Voriconazole | Antifungals | CYP2C19
Chloroquine | Antiinfectives | G6PD
Rifampin, Isoniazid, and Pyrazinamide | Antiinfectives | NAT1; NAT2
Abacavir | Antivirals | HLA-B*5701
Boceprevir | Antivirals | IL28B
Maraviroc | Antivirals | CCR5
Peginterferon alfa-2b | Antivirals | IL28B
Telaprevir | Antivirals | IL28B
Carvedilol | Cardiovascular | CYP2D6
Clopidogrel | Cardiovascular | CYP2C19
Isosorbide and Hydralazine | Cardiovascular | NAT1; NAT2
Metoprolol | Cardiovascular | CYP2D6
Prasugrel | Cardiovascular | CYP2C19
Pravastatin | Cardiovascular | ApoE2
Propafenone | Cardiovascular | CYP2D6
Propranolol | Cardiovascular | CYP2D6
Ticagrelor | Cardiovascular | CYP2C19
Cevimeline | Dermatology and Dental | CYP2D6
Dapsone | Dermatology and Dental | G6PD
Fluorouracil | Dermatology and Dental | DPD
Tretinoin | Dermatology and Dental | PML/RARα
Dexlansoprazole (1) | Gastroenterology | CYP2C19
Dexlansoprazole (2) | Gastroenterology | CYP1A2
Esomeprazole | Gastroenterology | CYP2C19
Omeprazole | Gastroenterology | CYP2C19
Pantoprazole | Gastroenterology | CYP2C19
Rabeprazole | Gastroenterology | CYP2C19
Sodium Phenylacetate and Sodium Benzoate | Gastroenterology | UCD (NAGS; CPS; ASS; OTC; ASL; ARG)
Sodium Phenylbutyrate | Gastroenterology | UCD (NAGS; CPS; ASS; OTC; ASL; ARG)
Lenalidomide | Hematology | Chromosome 5q
Warfarin (1) | Hematology | CYP2C9
Warfarin (2) | Hematology | VKORC1
Atorvastatin | Metabolic and Endocrinology | LDL receptor
Carisoprodol | Musculoskeletal | CYP2C19
Carbamazepine | Neurology | HLA-B*1502
Clobazam | Neurology | CYP2C19
Dextromethorphan and Quinidine | Neurology | CYP2D6
Galantamine | Neurology | CYP2D6
Phenytoin | Neurology | HLA-B*1502
Tetrabenazine | Neurology | CYP2D6
Aripiprazol | Psychiatry | CYP2D6
Atomoxetine | Psychiatry | CYP2D6
Chlordiazepoxide and Amitriptyline20 | Psychiatry | CYP2D6
Citalopram (1) | Psychiatry | CYP2C19
Citalopram (2) | Psychiatry | CYP2D6
Clomipramine | Psychiatry | CYP2D6
Clozapine | Psychiatry | CYP2D6
Desipramine | Psychiatry | CYP2D6
Diazepam | Psychiatry | CYP2C19
Doxepin | Psychiatry | CYP2D6
Fluoxetine | Psychiatry | CYP2D6
Fluoxetine and Olanzapine | Psychiatry | CYP2D6
Fluvoxamine (1) | Psychiatry | CYP2C9
Fluvoxamine (2) | Psychiatry | CYP2C19
Fluvoxamine (3) | Psychiatry | CYP2D6
Iloperidone | Psychiatry | CYP2D6
Imipramine | Psychiatry | CYP2D6
Modafinil (1) | Psychiatry | CYP2C19
Modafinil (2) | Psychiatry | CYP2D6
Nefazodone | Psychiatry | CYP2D6
Nortriptylin | Psychiatry | CYP2D6
Paroxetine | Psychiatry | CYP2D6
Perphenazin | Psychiatry | CYP2D6
Pimozide | Psychiatry | CYP2D6
Protriptylin | Psychiatry | CYP2D6
Risperidon | Psychiatry | CYP2D6
Thioridazine | Psychiatry | CYP2D6
Trimipramine | Psychiatry | CYP2D6
Valproic Acid | Psychiatry | UCD (NAGS; CPS; ASS; OTC; ASL; ARG)
Venlafaxine | Psychiatry | CYP2D6
Indacaterol | Pulmonary | UGT1A1
Ivacaftor | Pulmonary | CFTR (G551D)
Azathioprine | Rheumatology | TPMT
Flurbiprofen | Rheumatology | CYP2C9