# Evolution of Tests that were identified in the 2007 report

Table 1A Evolution of Tests that were identified in the 2007 report

Disease | Gene | FDA cleared | Currently available (2011)
Alpha-1-antitrypsin deficiency | SERPINA1 | n | y
Alport Syndrome | COL4A5 | n | y
Alzheimer's Disease | Phosphorylated-Tau protein, Total-Tau protein and Aß42 peptide | n | y
Alzheimer's Disease Late onset disease | ApoE2, E3, E4 alleles | n | y
Antithrombin-III Deficiency | SERPINC1 | n | y
Arrhythmogenic Right Ventricular Dysplasia/Cardiomyopathy | ARVD 1 to 9; RYR2, DSP, and PKP2 | n | y
Autosomal Dominant Nocturnal Frontal Lobe Epilepsy (ADNFLE) | CHRNA4, CHRNB2 | n | y
Bardet-Biedl Syndrome | BBS10 | n | y
Cardiovascular risk assessment | ACE I and II | n | y
Cerebral Autosomal Dominant Arteriopathy with Subcortical Infarcts and Leukoencephalopathy (CADASIL) | BBS2 | n | y
Cerebral Autosomal Dominant Arteriopathy with Subcortical Infarcts and Leukoencephalopathy (CADASIL) | BBS10 | n | y
CADASIL | NOTCH3 | n | y
Cerebral Cavernous Malformations | CCM2 | n | y
Cerebral Cavernous Malformations | CCM3 / PDCD10 | n | y
Familial Cerebral Cavernous Malformation 1 (CCM1) | CCM1 / KRIT1 | n | y
Crigler-Najjar Syndrome | UGT1A1 | y | y
Crohn Disease | CARD15 | n | y
Cystinosis | CTNS | n | y
Cystinuria | SLC3A1 | n | y
Cystinuria | SLC7A9 | n | y
Dent disease | CLCN5 | n | y
Dent disease | OCRL | n | y
Dentatorubral-Pallidoluysian Atrophy (Naito-Oyanagi Disease) | ATN1 | n | y
Familial Cold Urticaria | CIAS1 | n | y
Autosomal dominant frontotemporal dementia. | MAPT | n | y
Rare forms of thalassemia | Hemoglobin E | n | y
Hereditary Inclusion Body Myopathy | GNE gene | n | y
ACVRL1-Related Hereditary Hemorrhagic Telangiectasia | ACVRL1 (ALK1) | n | y
ENG-Related Hereditary Hemorrhagic Telangiectasia (Osler Rendu Weber Syndrome) | ENG | n | y
Hereditary Sensory Radicular Neuropathy Type I, HSN1 | SPTLC1 | n | y
Gilbert syndrome | UGT1A1 | y | y
Hexosaminidase A Deficiency or GM2 Gangliosidoses (Hexosaminidase A- Deficient) | HEXA | n | y
HFE-Associated Hereditary Hemochromatosis | HFE | n | y
Huntington Disease | HD | n | y
Huntington disease-like 2, HDL2 | JPH3 | n | y
Hyperbilirubinemia, rotor type | nd | n | y
Hyperlipoproteinemia Type III Risk Factor (APOE) | ApoE | n | y
Hypokalemic Periodic Paralysis Type 1 | CACNA1S | n | y
Hypokalemic Periodic Paralysis Type 2 | SCN4A | n | y
Krabbe Disease | GALC | n | y
Lecithin Cholesterol Acyltransferase Deficiency or Fish-Eye Disease or Norum Disease | LCAT | n | y
Marfan Syndrome | FBN1 | n | y
MASS Syndrome | FBN1 | n | y
Medullary Cystic Kidney Disease | UMOD | n | y
Membranoproliferative Glomerulonephritis, Type II | CFH | n | y
Metachromatic leukodystrophy | ARSA | n | y
Motor neuropathy | nd | n | y
Dilated cardiomyopathy | MYBPC3 | n | y
Dilated cardiomyopathy | MYH7 | n | y
Myoclonus-Dystonia | SGCE | n | y
Myotonic dystrophy type 1 | DMPK | n | y
Myotonic dystrophy type 2 | ZNF9 | n | y
Nemaline myopathy | NEB | n | y
Oculopharyngeal Muscular Dystrophy | PABPN1 | n | y
Osteoporosis | VDR | n | y
Paget Disease of Bone | PDB1 | n | y
Paget Disease of Bone | PDB2 | n | y
LRRK2-Related Parkinson Disease | LRRK2 | n | y
Pink1-Related Parkinson Disease | PINK1 | n | y
Patterned Dystrophy of Retinal Pigment Epithelium or Butterfly-Shaped Pigmentary Macular Dystrophy | RDS | n | y
Polycystic Kidney Disease | PKD1 and PKD2 genes | n | y
Polycystic liver disease | PRKCSH and SEC63 genes | n | y
Pompe Disease | GAA | n | y
Porphyria cutanea tarda or idiosyncratic porphyria | UROD | n | y
Primary open angle glaucoma | GLC1B | n | y
Primary open angle glaucoma | OPTN | n | y
Primary open angle glaucoma | MYOC | n | y
Primary pulmonary hypertension | BMPR2 | n | y
Red cell antigen genotyping (Duffy) | FY | n | y
Red cell antigen genotyping (Kidd) | SLC14A1 | n | y
Red cell antigen genotyping (Rh-e) | RHCE | n | y
Renal Tubular Acidosis, Distal, Autosomal Dominant | SLC4A1 | n | y
Renal Tubular Acidosis, Distal, Autosomal Recessive | ATP6V0A4 | n | y
Retinitis pigmentosa - PRPF3-Related Retinitis Pigmentosa | PRPF3 | n | y
Romano Ward (Long QT) Syndrome | KCNQ1 | n | y
Romano Ward (Long QT) Syndrome | KCNH2 | n | y
Romano Ward (Long QT) Syndrome | SCN5A | n | y
Romano Ward (Long QT) Syndrome | KCNE1 | n | y
Romano Ward (Long QT) Syndrome | KCNE2 | n | y
Sialuria | GNE | n | y
SOD1-Related Amyotrophic Lateral Sclerosis | SOD1 | n | y
Spastic Paraplegia Type 4 | SPAST | n | y
Spinal Muscular Atrophy 4 | SMN1 (SMNt) | n | y
Spinal and Bulbar Muscular Atrophy | AR | n | y
Spinocerebellar Ataxia Type 2 | ATXN2 | n | y
Spinocerebellar Ataxia Type 3 | ATXN3 | n | y
Spinocerebellar Ataxia Type 6 | CACNA1A | n | y
Spinocerebellar Ataxia Type 7 | ATXN7 | n | y
Spinocerebellar Ataxia Type 10 | ATXN10 | n | y
Spinocerebellar Ataxia Type 12 (SCA12) | PPP2R2B | n | y
Spinocerebellar ataxia type 14 (SCA14) | PRKCG | n | y
Spinocerebellar Ataxia Type 17 | TBP | n | y
Spastic Paraplegia 3 | SPG3A | n | y
Spastic Paraplegia 4 | SPAST | n | y
Thrombophilia | MTHFR | y | y
Thrombophilia | PROS1 | n | y
Thrombophilia | F5 | y | y
Transthyretin amyloidosis | TTR | n | y
Tuberous sclerosis I | TSC1 | n | y
Tuberous sclerosis 2 | TSC2 | n | y
XDx Allomap Molecular Expression testing for acute cellular organ transplant rejection | 11 different genes | y | y