# One-page summaries of genetic tests for non-cancer conditions

(All Medline searches were conducted on 3/1/2012)

Gene Test Information
- Test Name: Arrhythmogenic Right Ventricular Dysplasia/Cardiomyopathy Testing
  Gene Symbol: Five genes (PKP2; DSP; DSC2; DSG2; TMEM43)
  Protein Name: plakophilin; desmoplakin; desmocollin 2; desmoglein 2; transmembrane protein 43
  Description: Arrythmogenic Right Ventricular Dysplasia/Cardiomyopathy (ARVD/C) is an autosomal dominant genetic disorder that affects the desmosomes of cardiac muscle and accounts for approximately 20% of sudden cardiac deaths in young individuals and athletes. Commonly, the presenting symptom of ARVD/C is sudden cardiac death, and therefore genetic testing can detect at-risk individuals whose family members have a history of sudden cardiac death under age 45 or diagnosed ARVD/C.
  Purpose: Primary prevention; diagnostic
  Availability: Commercial labs
  Specimen: Whole blood
  Methodology: Amplification by polymerase chain reaction; sequencing of entire protein-coding region; deletion/duplication analysis. Diseases: Arrhythmogenic Right Ventricular Dysplasia/Cardiomyopathy
  Clinical Uses: Can be used to screen patients at risk for sudden cardiac death who may benefit from primary implantable cardiac defibrillator. Sources: correlagen.com
  Medline Searches: (PKP2[All Fields] OR "dsp"[All Fields]) OR DSC2[All Fields] OR DSG2[All Fields] OR TMEM43[All Fields]) AND ("cardiomyopathies"[MeSH Terms] OR "cardiomyopathies"[All Fields] OR "cardiomyopathy"[All Fields]) AND "humans"[MeSH Terms] = 99
  FDA Cleared: No

Gene Test Information
- Test Name: Atrial Septal Defect with Atrioventricular Block testing
  Gene Symbol: NKX2-5
  Protein Name: Transcription factors for NKX2-5.
  Description: Atrial Septal Defect with Atrioventricular Block is characterized by a congenital opening in the atrial septum in addition to defects in the atrioventricular node. NKX2-5 mutations are associated with atrial septal defect with atrioventricular block as well as sudden cardiac death. Therefore, testing in symptomatic individuals or those with a family history of the disease may be warranted for possible treatment by percutaneous closure of the septal defect.
  Purpose: Diagnostic testing
  Availability: Correlagen
  Specimen: Whole blood
  Methodology: Amplification by polymerase chain reaction; sequencing of entire protein-coding region.
  Diseases: Atrial Septal Defect with Atrioventricular Block testing
  Clinical Uses: Confirm diagnosis of atrial septal defect; alert risk of potential atrioventricular defect.
  Sources: correlagen.com
  Medline Searches: NKX2-5[All Fields] AND ("heart septal defects, atrial"[MeSH Terms] OR ("heart"[All Fields] AND "septal"[All Fields] AND "defects"[All Fields] AND "atrial"[All Fields]) OR "atrial heart septal defects"[All Fields] OR ("atrial"[All Fields] AND "septal"[All Fields] AND "defect"[All Fields]) OR "atrial septal defect"[All Fields]) AND "humans"[MeSH Terms] = 46
  FDA Cleared: No

Gene Test Information
- Test Name: Celiac Disease Profile-HLA Linkage Disequilibrium: DQA/DQB
  Gene Symbol: HLA-DQ2; HLA-DQ8
  Protein Name: Human Leukocyte Antigens HLA-DQ2; HLA-DQ8
  Description: HLA-DQ2; HLA-DQ8 genes, though common, have a strong association with the development of Celiac Disease, an autoimmune disorder characterized by gastrointestinal symptoms in response to consumption of gluten, a protein found in many grains. It is thought that the HLA-DQ2 and HLA-DQ8 antigens tightly bind, and present gluten peptides to antigen-specific T-cells, which induces T-cell proliferation and resulting inflammation and symptoms.
  Purpose: Diagnosis
  Availability: LabCorp; Quest Diagnostics
  Specimen: Blood; mouth swab
  Methodology: Not reported
  Diseases: Celiac Disease
  Clinical Uses: With high negative predictive value, testing may be performed to rule out Celiac Disease to alternative diagnoses.
  Sources: World J Gastroenterol. 2011 May 14;17(18):2259-72; LabCorp.com
  Medline Searches: (HLA-DQ2[All Fields] OR ("HLA-DQ8 antigen"[Supplementary Concept] OR "HLA-DQ8 antigen"[All Fields] OR "hla dq8"[All Fields])) AND ("coeliac disease"[All Fields] OR "celiac disease"[MeSH Terms] OR ("celiac"[All Fields] AND "disease"[All Fields]) OR "celiac disease"[All Fields]) AND "humans"[MeSH Terms] = 414
  FDA Cleared: No

Gene Test Information
- Test Name: Corus™ CAD
  Gene Symbol: 23 genes (IL18RAP; TNFAIP6; CASP5; IL8RB; TNFRSF10C; TLR4; KCNE3; S100A8; S100A12; CLEC4E; NCF4; RPL28; AQP9; SLAMF7; KLRC4; SPIB; CD79B; TMC8; CD3D; AF289562; HNRPF; TFCP2; TSPAN16)
  Protein Name: N/A
  Description: Corus™ CAD by CardioDX is a blood-base gene expression that integrates the expression levels of 23 genes and other patient characteristics to assess whether individual patient’s symptoms may be due to obstructive coronary artery disease (CAD). The patient’s blood sample is generally obtained in a primary care or cardiology clinic setting. Given that RNA levels are altered when obstructive CAD is present, the Corus CAD score aids clinicians in the diagnosis of obstructive coronary artery disease. Corus CAD is the first sex-specific test for CAD that accounts for key biological differences between men and women.
  Purpose: Diagnosis
  Availability: CardioDx, Inc
  Specimen: Blood sample
  Methodology: Quantitative real time polymerase chain reaction (qRT-PCR)
  Diseases: Coronary Artery Disease
  Clinical Uses: The test is intended to be used in an outpatient setting with non-diabetic, stable patients who present with typical or atypical symptoms suggestive of CAD, have no history of prior myocardial infarction (MI) or revascularization procedure, and are not currently taking steroids, immunosuppressive agents or chemotherapeutic agents.
  Sources: CardioDx® ; Annals of internal medicine citation
  Medline Searches: 4 citations available from manufacturer’s Web site.
  FDA Cleared: No

Gene Test Information
- Test Name: deCODE Cardio test Panel
  Gene Symbol: Five markers detected by deCODE AF™; CYP2C19 *2, *3, *4 and *8, and one SNP designated *17 detected by deCODE Clopidogrel™; DNA markers detected by deCODE MI™; DNA markers detected by deCODE T2™; two SNPs on chromosome 9 associated with increased risk of the development of abdominal aortic aneurysm; The deCODEC IA markers that include three SNPs (rs10757278, rs10958409, rs9298506) on chromosomes 8 and 9 associated with risk of IA; the F5 gene encoding factor V deCODE’s VTE test.
  Protein Name: Cytochrome P-450 enzymes and others
  Description: Many genetic variants, or SNPs, affect susceptibility to cardiovascular disease. The deCODE Cardio Scan measures the most comprehensive and up-to-date set of validated genetic risk factors for a range of CV diseases, including all of the risk markers for all of deCODE’s individual CV disease tests.
  Purpose: Diagnosis and risk assessment
  Availability: deCODE
  Specimen: Whole blood, buccal swab
  Methodology: ND
  Diseases: Cardiovascular risk factor assessment
  Clinical Uses: Informing, monitoring, and treatment strategies of cardiovascular diseases
  Sources: decodehealth.com
  Medline Searches: Not conducted due to multiple markers.
  FDA Cleared: No

Gene Test Information
- Test Name: deCODE Clopidogrel™
  Gene Symbol: CYP2C19 *2, *3, *4 and *8 (loss-of-function alleles), and one SNP designated *17 (the gain-of-function alleles)
  Protein Name: Cytochrome P-450 enzymes
  Description: Clopidogrel (trade name: Plavix), is an anti-platelet agent used in the treatment for coronary artery disease, peripheral vascular disease and cerebrovascular disease. Clopidogrel requires biotransformation to an active metabolite by cytochrome P-450 enzymes. Recent studies have shown that patients treated with Clopidogrel with a reduced function CYP C219 genetic variant had lower levels of the active metabolite resulting in a reduced antiplatelet response to the drug and a three-fold risk of stent thrombosis. The increased risk for recurrent cardiovascular events in patients with reduced anti-platelet response has been confirmed by several studies.
  Purpose: Therapeutic management
  Availability: deCODE Health
  Specimen: Not documented
  Methodology: Not documented
  Diseases: Poor metabolizers to clopidogrel / plavix
  Clinical Uses: Personalizing Clopidogrel dosing using pharmacogenetics may be an effective method of rationalizing treatment.
  Sources: http://www.decodehealth.com/clopidogrel-response
  Medline Searches: (CYP2C19[All Fields] OR (("cytochrome p-450 enzyme system"[MeSH Terms] OR ("cytochrome"[All Fields] AND "p-450"[All Fields] AND "enzyme"[All Fields] AND "system"[All Fields]) OR "cytochrome p-450 enzyme system"[All Fields] OR ("cytochrome"[All Fields] AND "p450"[All Fields]) OR "cytochrome p450"[All Fields]) AND 2C19[All Fields])) AND ("clopidogrel"[Supplementary Concept] OR "clopidogrel"[All Fields]) AND "humans"[MeSH Terms] = 254
  FDA Cleared: No (has added a Boxed Warning to the label of clopidogrel)

Gene Test Information
- Test Name: deCODE MI™
  Gene Symbol: Chromosome 9p21 variants
  Protein Name: Not documented
  Description: deCODE MI™ can detect genetic component to overall susceptibility to heart attack, risk that appears to be independent of well known risk factors such as elevated cholesterol and hypertension. Large clinical cohort studies have demonstrated that testing even for only the 9p21 markers included in deCODE MI™ shifts a significant proportion of patients either up or down in risk category, impacting guideline LDL targets and statin dosing.
  Purpose: Therapeutic management
  Availability: deCODE Health
  Specimen: Not documented
  Methodology: Not documented
  Diseases: Risk assessment of heart attack [myocardial infarction (MI)]
  Clinical Uses: Risk assessment of heart attack and management of cardiovascular risk factors.
  Sources: http://www.decodehealth.com/myocardial-infarction
  Medline Searches: (("chromosomes"[MeSH Terms] OR "chromosomes"[All Fields] OR "chromosome"[All Fields]) AND 9p21[All Fields]) AND (acute[All Fields] AND ("myocardial infarction"[MeSH Terms] OR ("myocardial"[All Fields] AND "infarction"[All Fields]) OR "myocardial infarction"[All Fields])) AND "humans"[MeSH Terms] = 10
  FDA Cleared: No

Gene Test Information
- Test Name: DNA Drug Sensitivity Testing™
  Gene Symbol: Multiple genes including CYP2D6, CYP2C9, CYP2C19, NAT2, UGT1A1, DPD, 5HTT, and CYP1A2
  Protein Name: Cytochrome P-450 enzymes and others
  Description: Screening of the following genes such as CYP2D6, CYP2C9, CYP2C19, NAT2, UGT1A1, DPD, 5HTT, and CYP1A2 can help predict a person's particular response to many prescription, OTC (over-the-counter) and herbal medicines including those used to treat depression, anxiety, seizures and psychoses; heart disease, cancer, diabetes, and pain. Screening for the aforementioned genes can identify the type of metabolizer including normal, intermediate, poor, and ultraextensive.
  Purpose: Therapeutic management
  Availability: Genelex.com
  Specimen: Buccal swab
  Methodology: Not documented
  Diseases: Adverse drug reactions to prescription or OTC medications
  Clinical Uses: Personalizing treatment and dosing using may be an effective method of treatment.
  Sources: http://www.healthanddna.com
  Medline Searches: (("cytochrome p-450 cyp2d6"[MeSH Terms] OR ("cytochrome"[All Fields] AND "p-450"[All Fields] AND "cyp2d6"[All Fields]) OR "cytochrome p-450 cyp2d6"[All Fields] OR "cyp2d6"[All Fields]) OR CYP2C9[All Fields] OR CYP2C19[All Fields] OR NAT2[All Fields] OR UGT1A1[All Fields] OR DPD[All Fields] OR 5HTT[All Fields] OR ("cytochrome p-450 cyp1a2"[MeSH Terms] OR ("cytochrome"[All Fields] AND "p-450"[All Fields] AND "cyp1a2"[All Fields]) OR "cytochrome p-450 cyp1a2"[All Fields] OR "cyp1a2"[All Fields])) AND ("pharmacogenetics"[MeSH Terms] OR "pharmacogenetics"[All Fields] OR "pharmacogenomics"[All Fields]) AND "humans"[MeSH Terms] = 1559
  FDA Cleared: No (but the aforementioned genes are labeled on medications as Boxed Warning label)

Gene Test Information
- Test Name: Familial Dilated cardiomyopathy
  Gene Symbol: Associated with any of at least 24 genes, including ACTC; LMNA; MYH7; TNNT2; MYBPC3; TNNI3; TPM1.
  Protein Name: Includes lamin A; cardiac myosin heavy chain, beta; cardiac troponin T; myosin binding protein C.
  Description: Dilated cardiomyopathy (DCM) is characterized by an enlarged left ventricle with diminished ability to pump blood, leading to progressive heart failure. While there are several types of DCM, familial DCM accounts for approximately 30–60% of cases. Screening at-risk individuals for familial mutations in any one of these 24 genes may identify affected individuals for treatment.
  Purpose: Diagnostic
  Availability: Available at major lab testing centers
  Specimen: Whole blood
  Methodology: Amplification by polymerase chain reaction (PCR); sequencing of entire protein-coding region
  Diseases: Dilated cardiomyopathy
  Clinical Uses: Test may be used to identify sporadic versus familial DCM.
  Sources: correlagen.com; NCBI Genetic Testing Registry
  Medline Searches: (ACTC[All Fields] OR LMNA[All Fields] OR MYH7[All Fields] OR TNNT2[All Fields] OR MYBPC3[All Fields] OR TNNI3[All Fields] OR TPM1[All Fields]) AND ("cardiomyopathy, dilated"[MeSH Terms] OR ("cardiomyopathy"[All Fields] AND "dilated"[All Fields]) OR "dilated cardiomyopathy"[All Fields] OR ("dilated"[All Fields] AND "cardiomyopathy"[All Fields])) AND "humans"[MeSH Terms] = 189
  FDA Cleared: No

Gene Test Information
- Test Name: Familial Hypercholesterolemia
  Gene Symbol: LDLR; APOB; (PCSK9)
  Protein Name: Low-density lipoprotein receptor; apolipoprotein
  Description: Familial Hypercholesterolemia is an autosomal co-dominantly inherited disease. Gene LDLR codes for the low-density lipoprotein receptor (LDLR), the main mediator for clearance of low-density lipoprotein from the plasma. Individuals heterozygous for a mutation in LDLR show diminished expressivity of LDLR, and therefore have high LDL cholesterol levels. Homozygous individuals have even higher levels. Significantly high levels of LDL often lead to coronary heart disease.
  Purpose: Diagnosis
  Availability: Wide use
  Specimen: Blood
  Methodology: To verify genetic bases for hypercholesterolemia and to guide treatment
  Diseases: Hypercholesterolemia
  Clinical Uses: Amplification by polymerase chain reaction; sequencing of entire protein-coding region.
  Sources: correlagen.com
  Medline Searches: (LDLR[All Fields] OR ("apolipoproteins b"[MeSH Terms] OR "apolipoproteins b"[All Fields] OR "apob"[All Fields]) OR PCSK9[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields]) AND ("familial hypercholesterolaemia"[All Fields] OR "hyperlipoproteinemia type ii"[MeSH Terms] OR ("hyperlipoproteinemia"[All Fields] AND "type"[All Fields] AND "ii"[All Fields]) OR "hyperlipoproteinemia type ii"[All Fields] OR ("familial"[All Fields] AND "hypercholesterolemia"[All Fields]) OR "familial hypercholesterolemia"[All Fields]) AND "humans"[MeSH Terms] = 297
  FDA Cleared: No

Gene Test Information
- Test Name: Long QT Syndrome gene analyses (CPT code: 812XX)
  Gene Symbol: Duplication-deletion variants - KCNQ1, KCNH2, SCN5A, KCNE1, KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1, ANK2
  Protein Name: N/A
  Description: This test is an add-on to the original diagnosis test of Romano Ward Syndrome with the addition of the following genes: KCNQ1, KCNH2, SCN5A, KCNE1, KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1 and ANK2.
  Purpose: Diagnostic, Prognostic
  Availability: Clinical laboratories
  Specimen: Blood
  Methodology: Duplication/Deletion Variants
  Diseases: Romano Ward (Long QT) Syndrome
  Clinical Uses: Clinical use(s) for the Medicare population: (a) Confirmatory diagnostic testing; (b) Predictive testing
  Sources: American Medical Association’s (AMA) Current Procedural Terminology (CPT) Editorial Panel 2012
  Medline Searches: (KCNQ1[All Fields] OR KCNH2[All Fields] OR SCN5A[All Fields] OR KCNE1[All Fields] OR KCNJ2[All Fields] OR CACNA1C[All Fields] OR CAV3[All Fields] OR SCN4B[All Fields] OR AKAP[All Fields] OR SNTA1[All Fields] OR ANK2[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields]) AND ("long qt syndrome"[MeSH Terms] OR ("long"[All Fields] AND "qt"[All Fields] AND "syndrome"[All Fields]) OR "long qt syndrome"[All Fields]) AND "humans"[MeSH Terms] = 333
  FDA Cleared: Yes

Gene Test Information
- Test Name: Long QT Syndrome gene analyses (familial sequence variant)
  Gene Symbol: Familial sequence variant - KCNQ1, KCNH2, SCN5A, KCNE1, KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1, ANK2
  Protein Name: N/A
  Description: This test is an add-on to the original diagnosis test of Romano Ward Syndrome with the addition of the following genes: KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1 and ANK2.
  Purpose: Diagnostic, Prognostic
  Availability: Clinical laboratories
  Specimen: Blood
  Methodology: Full Sequence Analysis
  Diseases: Romano Ward (Long QT) Syndrome
  Clinical Uses: Clinical use(s) for the Medicare population: (a) Confirmatory diagnostic testing; (b) Predictive testing
  Sources: American Medical Association’s (AMA) Current Procedural Terminology (CPT) Editorial Panel 2012
  Medline Searches: (KCNQ1[All Fields] OR KCNH2[All Fields] OR SCN5A[All Fields] OR KCNE1[All Fields] OR KCNJ2[All Fields] OR CACNA1C[All Fields] OR CAV3[All Fields] OR SCN4B[All Fields] OR AKAP[All Fields] OR SNTA1[All Fields] OR ANK2[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields]) AND ("long qt syndrome"[MeSH Terms] OR ("long"[All Fields] AND "qt"[All Fields] AND "syndrome"[All Fields]) OR "long qt syndrome"[All Fields]) AND "humans"[MeSH Terms] = 333
  FDA Cleared: Yes

Gene Test Information
- Test Name: Long QT Syndrome gene analyses (CPT code: 812XX)
  Gene Symbol: KCNQ1, KCNH2, SCN5A, KCNE1, KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1, ANK2
  Protein Name: N/A
  Description: This test is an add-on to the original diagnosis test of Romano Ward Syndrome with the addition of the following genes: KCNQ1, KCNH2, SCN5A, KCNE1, KCNJ2, CACNA1C, CAV3, SCN4B, AKAP, SNTA1, and ANK2
  Purpose: Diagnostic, Prognostic
  Availability: Clinical laboratories
  Specimen: Blood
  Methodology: Known Familial Sequence Variant
  Diseases: Romano Ward (Long QT) Syndrome
  Clinical Uses: Clinical use(s) for the Medicare population: (a) Confirmatory diagnostic testing; (b) Predictive testing
  Sources: American Medical Association’s (AMA) Current Procedural Terminology (CPT) Editorial Panel 2012
  Medline Searches: (KCNQ1[All Fields] OR KCNH2[All Fields] OR SCN5A[All Fields] OR KCNE1[All Fields] OR KCNJ2[All Fields] OR CACNA1C[All Fields] OR CAV3[All Fields] OR SCN4B[All Fields] OR AKAP[All Fields] OR SNTA1[All Fields] OR ANK2[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields]) AND ("long qt syndrome"[MeSH Terms] OR ("long"[All Fields] AND "qt"[All Fields] AND "syndrome"[All Fields]) OR "long qt syndrome"[All Fields]) AND "humans"[MeSH Terms] = 333
  FDA Cleared: Yes

Gene Test Information
- Test Name: The Ambry test: Marfan Syndrome and Marfan-Related Disorders Next-Gen Sequencing Panel
  Gene Symbol: ACTA2, CBS, FBN1, FBN2, MYH11, COL3A1, SLC2A10, SMAD3, TGFBR1 and TGFBR2 genes
  Protein Name: Not documented
  Description: Marfan Syndrome is an autosomal dominant, multisystem disorder characterized by cardiovascular, skeletal, and ocular abnormalities. One of the major features of Marfan syndrome (MFS) and the majority of Marfan- related disorders is an increased risk for Thoracic Aortic Aneurysms (TAAs), which if left untreated, has a high morbidity and mortality rate. Three genes have been associated with familial nonsyndromic TAAs: TGFBR2 in TAA2, ACTA2 in TAA4, MYH11 in familial TAA and patent ductus arteriosus. Sporadic forms of TAAs have also been reported. To date, ten genes (ACTA2, CBS, FBN1, FBN2, MYH11, COL3A1, SLC2A10, SMAD3, TGFBR1, and TGFBR2) have been associated with various forms of MFS and Marfan-related syndromes.
  Purpose: Prognosis, Therapeutic management
  Availability: Ambry Genetics™
  Specimen: Whole blood, buccal swab
  Methodology: Polymerase chain reaction (PCR) and Next-Gen sequencing and Sanger sequencing
  Diseases: Marfan Syndrome (MFS) and Marfan Syndrome related disorders
  Clinical Uses: Can aid diagnosis and management in patients suspected to have Marfan Syndrome and Marfan Syndrome related disorders. The test may also be considered for differential diagnosis, carrier testing for individuals with a family history.
  Sources: http://www.ambrygen.com/panels/marfan-syndrome-and-marfan-related-disorders-next-gen-sequencing-panel
  Medline Searches: (ACTA2[All Fields] OR CBS[All Fields] OR FBN1[All Fields] OR FBN2[All Fields] OR MYH11[All Fields] OR COL3A1[All Fields] OR SLC2A10[All Fields] OR SMAD3[All Fields] OR TGFBR1[All Fields] OR TGFBR2[All Fields]) AND MARFAN[All Fields] AND "humans"[MeSH Terms] = 366
  FDA Cleared: No

Gene Test Information
- Test Name: Narcolepsy Profile
  Gene Symbol: HLA-DRB1*15; DQB1*0602
  Protein Name: Not documented
  Description: Narcolepsy is a nervous system disorder characterized by excessive sleepiness and frequent daytime sleep attacks. The etiology is not fully known, though it is associated with the DRB1/DQB1 alleles.
  Purpose: Research purpose, Therapeutic management
  Availability: LabCorp and other international laboratories
  Specimen: whole blood
  Methodology: Polymerase chain reaction – targeted mutation analysis
  Diseases: Narcolepsy, cataplexy
  Clinical Uses: Diagnosis; research.
  Sources: labcorp.com; PubMed
  Medline Searches: (HLA-DRB1*15[All Fields] OR ("HLA-DQB1 antigen"[Supplementary Concept] OR "HLA-DQB1 antigen"[All Fields] OR "dqb1 0602"[All Fields])) AND ("genes"[MeSH Terms] OR "genes"[All Fields]) AND ("narcolepsy"[MeSH Terms] OR "narcolepsy"[All Fields]) AND "humans"[MeSH Terms] = 57
  FDA Cleared: No

Gene Test Information
- Test Name: Pan Cardiomyopathy Panel
  Gene Symbol: Pan Cardiomyopathy Panel - 46 genes (HCM panel 18 genes; DCM panel 24 genes; ARVC/CPVT panel 8 genes; and LVNC panel 10 genes)
  Protein Name: N/A
  Description: Hypertrophic cardiomyopathy (HCM) is characterized by unexplained left ventricular hypertrophy (LVH) in a non-dilated ventricle. To date, over 1000 variants have been identified in genes causative of HCM, most of which affect the sarcomere, the contractile unit of the cardiac muscle. Dilated cardiomyopathy (DCM) is characterized by ventricular chamber enlargement and systolic dysfunction with normal left ventricular wall thickness. To date, over 40 genes have been demonstrated to cause DCM. Arrhythmogenic Right Ventricular Cardiomyopathy (ARVC) is characterized by replacement of myocytes by fatty or fibrofatty tissue, mainly in the right ventricle. The resulting manifestations are broad and include ventricular tachyarrhythmias and sudden death in young individuals and athletes. ARVC is typically inherited in an autosomal dominant fashion with incomplete penetrance and variable expressivity and to date, 5 ARVC genes (DSP, DSC2, DSG2, PKP2, TMEM43) have been identified. Catecholaminergic polymorphic ventricular tachycardia (CPVT) is typically characterized by exercise induced syncope due to ventricular tachycardia in individuals without structural heart disease. Two CPVT genes are known to date (RYR2 – autosomal dominant; CASQ2 – autosomal recessive). Left ventricular noncompaction (LVNC) has recently been established as a specific type of cardiomyopathy and is often familial, and the genetic spectrum is beginning to emerge although it is not yet well defined. LVNC genes reported to date include ACTC, DTNA, LDB3, MYBPC3, MYH7, TAZ, and TNNT2.
  Purpose: Clinical diagnosis, Therapeutic management
  Availability: Center for Personalized Genetic Medicine, Harvard Medical School.
  Specimen: Whole blood
  Methodology: A combination of next generation sequencing technology and Sanger sequencing
  Diseases: Hypertrophic cardiomyopathy (HCM); Dilated cardiomyopathy (DCM); Arrhythmogenic Right Ventricular Cardiomyopathy (ARVC); Catecholaminergic polymorphic ventricular tachycardia (CPVT); and Left ventricular noncompaction (LVNC)
  Clinical Uses: Patients with unclear diagnosis and those who have a family history where the number of living affected relatives would allow segregation analysis to establish or rule out pathogenicity.
  Sources: http://pcpgm.partners.org/lmm/tests/cardiomyopathy
  Medline Searches: Not conducted due to many genes.
  FDA Cleared: No

Gene Test Information
- Test Name: Pulmonary Arterial Hypertension (BMPR2)
  Gene Symbol: BMPR2 DD
  Protein Name: Bone morphogenetic protein
  Description: Primary pulmonary arterial hypertension (PAH) is caused by wide spread occlusion/destruction of the smallest pulmonary arteries that increases resistance to blood flow. Most heritable PAH (75%) is caused by a mutation in BMPR2. Heritable PAH is autosomal dominant. Retrospective studies suggest that persons with PAH who have a BMPR2 mutation exhibit more severe disease.
  Purpose: Diagnosis
  Availability: Arup laboratories; Ambry genetics
  Specimen: Whole blood
  Methodology: Polymerase Chain Reaction/Multiplex Ligation-dependent Probe Amplification to detect Deletion/Duplication
  Diseases: Primary pulmonary arterial hypertension
  Clinical Uses: Detection of PAH and management
  Sources: Arup laboratories; GeneReviews
  Medline Searches: (("bone morphogenetic protein receptors, type ii"[MeSH Terms] OR ("bone"[All Fields] AND "morphogenetic"[All Fields] AND "protein"[All Fields] AND "receptors"[All Fields] AND "type"[All Fields] AND "ii"[All Fields]) OR "type ii bone morphogenetic protein receptors"[All Fields] OR "bmpr2"[All Fields]) AND ("genes"[MeSH Terms] OR "genes"[All Fields] OR "gene"[All Fields]) AND ("hypertension, pulmonary"[MeSH Terms] OR ("hypertension"[All Fields] AND "pulmonary"[All Fields]) OR "pulmonary hypertension"[All Fields] OR ("pulmonary"[All Fields] AND "hypertension"[All Fields]))) AND "humans"[MeSH Terms] = 159
  FDA Cleared: No