# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Diane Allingham-Hawkins, Ph.D.
  Director, Genetic Test Evaluation Program
  Hayes, Inc
  157 South Broad Street
  Lansdale, PA 19446-3853
- Marta Gwinn, M.D., M.P.H.
  Office of Genetics and Disease Prevention
  Centers for Disease Control and Prevention
  4770 Buford Highway
  Atlanta, GA 30341-3724
- James Haddow, M.D.
  Professor of Pathology & Laboratory Medicine (Research)
  Brown University
  75 Waterman Street
  Providence
  RI 02912