# References

1 Bochud M. Genetics for clinicians: From candidate genes to whole genome scans (technological advances). Best Pract Res Clin Endocrinol Metab. Apr. 2012;26(2):119-132. [pmid: 22498243].
2 Khoury MJ, Dorman JS. The Human Genome Epidemiology Network. Am J Epidemiol. Jul. 1. 1998;148(1):1-3. [pmid: 9663396].
3 Khoury MJ, Millikan R, Little J, et al. The emergence of epidemiology in the genomics age. Int J Epidemiol. Oct. 2004;33(5):936-944. [pmid: 15319400].
4 Raman G, Chew P, Trikalinos TA, et al. Genetic Tests for Non-Cancer Diseases/Conditions: A Horizon Scan. 2007. PMID: None.
5 Raman G, Wallace B, Chung M, et al. Update on Genetic Tests for Non-Cancer Diseases/Conditions: A Horizon Scan. 2010. Accessed on May 18, 2012. Available at: http://www.cms.gov/Medicare/Coverage/DeterminationProcess/downloads//id49ta2.pdf.
6 New frontiers in grey literature: GL'99 proceedings. Fourth International Conference on Grey Literature. Washington, D.C. GreyNet. 1999. PMID: None.
7 Kuehn BM. NIH launching genetic test registry. JAMA. May. 5. 2010;303(17):1685. [pmid: 20442379].
8 Gwinn M, Grossniklaus DA, Yu W, et al. Horizon scanning for new genomic tests. Genet Med. Feb. 2011;13(2):161-165. [pmid: 21233720].
9 Raman G, Trikalinos TA, Zintzaras E, et al. Reviews of Selected Pharmacogenetic Tests for Non-Cancer and Cancer Conditions. 2008. PMID: None.
10 Zintzaras E, Raman G, Kitsios G, et al. Angiotensin-converting enzyme insertion/deletion gene polymorphic variant as a marker of coronary artery disease: a meta-analysis. Arch Intern Med. May. 26. 2008;168(10):1077-1089. [pmid: 18504336].
11 Zintzaras E, Kitsios GD, Triposkiadis F, et al. APOE gene polymorphisms and response to statin therapy. Pharmacogenomics J. Aug. 2009;9(4):248-257. [pmid: 19529002].