# Results

Currently, the Gene Test Tracker database contains 112 different genetic tests logged into 161 test-disease combinations. We identified 50 new genetic tests for common cancer conditions since the 2006 report, with the largest number of tests being utilized for breast cancer, colorectal cancer, multiple cancers, lung cancer, and prostate cancer (Table 2). Of these, 16 tests were identified through internet searches alone, 21 tests matured to clinical use of the 104 that were identified as tests “in development” in our 2006 report; and 13 tests were identified by experts during the peer review process. The one-page description for these newly identified genetic tests for cancer conditions can be found in Appendix A. These tests are used in a variety of solid tumors and hematological cancers.

Of the 104 tests that were identified as tests in development in our 2006 report, only 21 tests matured to full clinical use (Appendix B). One test (PyloriProbe) has been voluntarily withdrawn from the market, two tests that were identified as those used in the context of aspiration of cervical or breast specimens were excluded, and one test was excluded since it was identified as evaluating genetic material of infectious agent (digene High-Risk HPV HC2 DNA Test). The remaining 79 tests are currently being tracked as tests in development or in research. In addition, one test (PreGen Plus) which was identified as a test in clinical use in our 2006 report has also been withdrawn voluntarily from the market.

Table 2 Genetic tests for cancer found between January, 2006 and February 2011

Test Name | Purpose
| Prognostic/ Predictive | Diagnostic | Monitoring | Recurrence | Therapeutic management | Primary prevention | Secondary prevention
Breast
Breast Profile | | | | | x
deCODE BreastCancer™ | X | X
GeneSearch™ BLN Assay | X | X
Her2 Neu Overexpression | | | | | X
Her2 Pro™ | | X | | | X
MammaPrint® | X | X
SPOT-Light ®HER2 CISH Kit | | | | | X
Tamoxitest™ | | | | | X
TOP2A FISH pharmDx™ Kit | X | | X
Colorectal
BRAF mutation | X | X | | | X
ColonSentry™ | | | | | | X
Colopath®/ColorectAlert™ | | X
Cytokeratin 20(CK 20) | | X
KRAS Mutation Analysis | X
Oncotype DX® colon cancer assay | | | | X | | | X
Septin-9 DNA methylation biomarker | | X
UGT1A1 Molecular Assay™ | | | | | X
Genitourinary
ImmunoCyt™/uCyt+™ | | | X
NMP22®BladderChek® | | X
Hematologic
G6PD | | | | | X
Heme Profile | X
JAK2 | | X | | | X
KIT Asp816Val Mutation Analysis | | X | | | X
Lung
CellCorrect KvA-40 Lab® Kit | | X
EGFR Mutation Analysis | | | | | X
ELSA-CYFRA 21-1 | X | X
ERCC1 | | | | | X
KRAS Mutation Analysis | X | | | | X
MESOMARK® | | X | | | X
Ovarian
OVA1™ | X | | | | | | X
OvaCheck™ | | X
OvaSure™ | | X
Prostate
Bayer Immuno 1™ Complexed PSA | | X | X
deCODE Prostate Cancer | | X
Hybritech Tandem-R free PSA test | | X | | | | X
Progensa® PCA3 Assay | X | X | | | X
Prostate-63 | | | | | | X
uPM3™ test; PCA3Plus™ test | X | X
Other^**^
DakoCytomation’s c-Kit (9.7) pharmDx™ | | X | | | X
LBA®AFP-L3 | | | | | | X
MGMT methylation testing | | | | | X
Multiple^***^
CellSearch® | X | | X | X
CupPrint | | X
DPD deficiency | | | | | | X
EGFR™ assay | | | | | | X
miRview™ | | X
Pathwork® Tissue of Origin test | | X
PI3K | X
TheraGuide™ | | | | | X
Tumor Profile | X

** Other includes brain, liver, and upper gastrointestinal, respectively

*** Tests used for multiple cancers including breast, colorectal, lung, ovarian, prostate