# Methods

We adopted the 2006 horizon scan report Genetic Testing for Cancer Conditions (by the Tufts-EPC) as a model for this report. We adopted all the terminologies used in the previous report. The current report updates the database of genetic tests for cancer conditions, and provides concise summaries for all newly identified tests since 2006. For readers’ convenience, some sections from the 2006 horizon scan report on Genetic Testing for Cancer are reproduced in the Methods section. The items that are bold-faced and italicized pertain to new entries in the Methods section.

## Terminologies and definitions

### Genetic test

We adopted specific sections of the updated genetic test definition from the 2008 Report of the Secretary’s Advisory Committee on Genetics, Health, and Society (SACGHS) (http://oba.od.nih.gov/).

“A genetic or genomic test involves an analysis of human chromosomes, deoxyribonucleic acid, ribonucleic acid, genes, and/or gene products (e.g., enzymes and other types of proteins), which is predominately used to detect heritable or somatic mutations, genotypes, or phenotypes related to disease and health. The purpose of genetic tests includes predicting risk of disease, screening newborns, directing clinical management, identifying carriers, and establishing prenatal or clinical diagnoses or prognoses in individuals, families, or populations. Excluded from the definition are tests conducted exclusively for forensic and identity purposes as well as tests conducted purely for research. Also excluded are tests that are used primarily for other purposes but that may contribute to diagnosing a genetic disease or disorder (e.g., blood smears, certain serum chemistries). For example, cholesterol screening in the general population is not considered a genetic test, but it may reveal a genetic disorder such as an inherited form of hypercholesterolemia”.

This definition includes genetic variations, panels of genetic markers, measurements of gene expression and transcription products, biochemical biomarkers, topographic genotyping, and cytogenetic tests. The terms “genetics” and “genomics” are often used interchangeably in the literature, and both can refer to tests for molecular or biochemical biomarkers, as well as cytogenetic and gene-based tests. In general, the genetic tests for cancer conditions have no specific names and are usually named after the disease/condition and/or by the gene and methodology of the specific genetic test. Thus, the name of a genetic test can vary from one laboratory to another. Therefore, the types of genetic tests in this report also include genomic, pharmacogenomic, proteomic, and other tests as reported by the individual manufacturers or laboratories. We summarized all genetic tests that provide diagnostic and prognostic information, monitor patient status, or detect disease recurrence.

### Eligibility criteria

#### Inclusion criteria

Similar to the criteria listed in the 2006 horizon scan report Genetic Testing for Cancer Conditions (by the Tufts-EPC), we considered genetic tests that have applications in the common solid tumors (breast, lung, colorectal, pancreas, etc.) as well as tests that are used in hematologic cancers (leukemia, lymphoma). We included genetic tests that are already in clinical practice. The population of interest was adults with more applicability to the Medicare age group. We included genetic tests that are performed to aid in diagnosing, treating, predicting, and prognosticating cancers that commonly occur in adult patients. In addition, we also included tests that were utilized to monitor patient status and detect disease recurrence. More recently, in consultation with the AHRQ and CMS, we included genetic tests based on any one of the following selection criteria:

1. Genetic tests that have been cleared by FDA or pending clearance by FDA.
2. Genetic tests that are conducted in Clinical Laboratory Improvement Amendments (CLIA) certified labs and require a physician order.
3. Genetic tests offered by Internet sites that specifically require a physician order.

#### Exclusion criteria

We excluded tests that are performed for conditions that exclusively result in early death before reaching adulthood. We also excluded tests performed for the purpose of identifying noncancer conditions.

## Clinical Applications of Genetic Tests

For the clinical applications of genetic tests that are covered in this report, we adapted the Tufts-EPC 2006 horizon scan report, Genetic Testing for Cancer. The following categories were used to describe the different applications for various genetic tests:

i. Prevention (primary or secondary): to detect inherited susceptibility to cancer in persons who do not have cancer in order to initiate appropriate interventions, or to detect cancer in persons who have early stage (asymptomatic) cancer.
ii. Diagnosis and management: includes confirming, classifying, and predicting typical course of cancer, choosing type of treatment (e.g. surgery alone or with adjuvant chemotherapy), monitoring response to therapy, choosing the right drug in the right dose at the right frequency (pharmacogenomics).

Tests were further classified into diagnostic, prognostic, predictive, recurrence, and monitoring categories:

1. Diagnostic: used to confirm or aid in the diagnosis of the particular disease.
2. Prognostic: information from the test can be used to determine or predict the aggressiveness of the disease or overall outcome of the disease at the time of initial diagnosis and prior to initiation of treatment. Prognostic information can then be used to determine a particular or individualized treatment plan.
3. Predictive: information from the test can be used to determine or predict the response of the disease or overall outcome of the disease with treatment.
4. Recurrence: to detect disease recurrence in a patient who has already been diagnosed and treated for cancer.
5. Monitoring: test used to monitor tumor and/or patient response to treatment.

## Literature searches

Our previous experience suggests that systematic searches of the published scientific literature are not a practical way to identify new genetic tests for the following reasons: 1) there are no specific pre-defined search strategies to identify genetic tests that are currently available in clinical use; 2) the large volume of publications on genetic, genomic, proteomic, and related molecular markers and panels makes review too resource intensive; 3) typically publications referring to specific patented technologies may not be indexed by their genetic test names, as the main focus may be to study molecular expression patterns or gene-disease associations; 4) even if a test is currently in clinical use and there are studies that pertain to the test of interest, there may still be a time lag until their publication; and 5) many potentially evaluated gene-disease associations may not have matured to a clinically useful genetic test.

Based on our experience with two prior technology assessment reports on genetic tests for cancer and noncancer conditions, focused searches of the grey literature are preferable to searches of the published scientific literature for the identification of new genetic tests.

### Description of grey literature sources

The contents in this section were obtained directly from manufacturers’ Web sites or other commercial Web sites, and should not be considered as verified information.

1. GeneTests (www.genetests.org) is a Web site funded by the National Institutes of Health and sponsored by the University of Washington in Seattle. The current Web site includes links to the International Laboratory Directory, the International Genetics Clinic Directory, GeneReviews, and Educational Materials. The purpose of this Web site is to provide medical genetics information to physicians, other healthcare providers, and researchers. GeneTests.org is available free of charge to all interested persons. GeneReviews is authored and reviewed by experts in the field of genetics, updated and/or revised periodically as clinically relevant material emerges. GeneReviews allows searches to be conducted by disease name, gene symbol, chromosomal locus, protein name, feature, Online Mendelian Inheritance in Man (OMIM) number, author, or title. The GeneTests.org reports that the International Laboratory Directory is a voluntary listing of laboratories offering molecular genetic testing, specialized cytogenetic testing, and biochemical testing for inherited disorders. We obtained information related to testing, clinical uses, and other resources from the GeneReviews section of the GeneTests.org Web site. We also utilized the links to commercial diagnostic laboratories that were provided by testing sources to explore the specimen collection methods, methodology, and genetic disease/condition descriptions.
2. We searched Internet Web sites using the following algorithm. We first searched Google News (http://www.news.google.com) for the following: “gene, genetic, genomic, pharmacogenomic, epigenetic” and “FDA + cleared genetic test.” The news items with their links were automatically deposited into an email system to generate daily email alerts. Periodically, we visited Web links listed in the news items weekly. We also visited the relevant laboratories that appeared in the news items to identify any new genetic tests. The Web links that identify potentially eligible tests are stored in a spreadsheet.
3. Commercial diagnostic laboratories’ Web sites were screened to identify genetic tests that are available for routine clinical use. We also identified the Web pages of companies or major commercial laboratories in the United States, such as Roche Diagnostics^®^, Quest Diagnostics^®^, and LabCorp^®^. A selected list of systematically queried laboratories and their Web sites can be found in Table 1. The websites of the major laboratories are visited once quarterly every year. For any potential genetic tests that were mentioned in these Web sites, we conducted focused Internet searches by including the specific test names to find more information, including other manufacturers, suggested uses, and press releases.
  Table 1 Selected list of Websites that were reviewed to identify new genetic tests for cancers
  Description | URL
  Quest Diagnostics^®^ | http://www.questdiagnostics.com/
  LabCorp^®^ | http://www.labcorp.com/
  Roche Diagnostics^®^ | http://www.roche-diagnostics.us/
  Athena Diagnostics, Inc | http://www.athenadiagnostics.com
  GeneDx | http://www.genedx.com
  Abbott Molecular Laboratories | http://www.abbottmolecular.com
  Google News | http://news.google.com
  FDA News | http://FDAnews.com
  Genelex Corporation | http://www.healthanddna.com/
  deCODE Genetics Inc. | http://www.decode.com/
  Medical Solutions Ltd. (Nottingham) | http://www.medical-solutions.co.uk/default.aspx
  PreMD, Inc. (formerly IMI International Medical Innovations) | http://www.premdinc.com/
  DiagnoCure | http://www.diagnocure.com/en/index.php
  Epigenomics | http://www.epigenomics.com/
  Correlogic | http://www.correlogic.com/
  Matritech, Inc. | http://www.matritech.com/
  Agendia | http://www.agendia.com/
  Caris Life Sciences | http://www.molecularprofiling.com/
  Monogram Biosciences | http://www.monogrambio.com/
  Bostwick Laboratories | http://www.bostwicklaboratories.com/home/
  Genzyme Genetics | http://www.genzymegenetics.com/
  Arup Laboratories | http://www.aruplab.com/
  Wako Chemicals USA, Inc | http://www.wakousa.com/
  Veridex, LLC | http://www.veridex.com/
  CeMines, Inc. | http://www.cemines.com/
  Dako (formerly DakoCytomation) | http://www.dako.com/
  Ambrilia Biopharma Inc. | http://www.ambrilia.com/en/index.php
  Clarient, Inc | http://www.clarientinc.com/
4. Other internet sites: At the direction of experts in the field of genetics, we included tests available at the following Web sites PHG Foundation (phgfoundation.org), EGAPP Reviews (egappreviews.org), and Association for Molecular Pathology (amp.org).
5. The two currently developing fields of pharmacogenetics (focuses on single genes) and pharmacogenomics (focuses on multiple genes) may provide insights into the inter-individual variability in drug responses. We identified genetic tests from the PharmGKB Web site (pharmgkb.org) maintained by Stanford University.

## Individual test summaries

Once the list of current genetic tests was identified, one-page summaries of each test in the database were completed using data extracted from various sources, including laboratory Web sites and test manufacturer Web sites. Data included in these summaries are a more detailed description of the test and its clinical use. The “one-page summary” included the following items:

1. Test name: The majority of the clinically available genetic tests were identified either by the disease/conditions or by the disease causing genes without any specific test name. Hence the gene names, protein, and disease/conditions served as the surrogate for the genetic testing identifier. When available, we recorded the specific test name.
2. Description: Included a brief summary of the genetic or genomic test and its association with the cancer condition.
3. Purpose: The clinical applications of genetic tests included primary or secondary prevention, diagnostic, prognostic, predictive, recurrence, monitoring, and therapeutic management.
4. Availability: Included a brief list of laboratories including commercial and academic laboratories in the U.S. and other countries.
5. Specimen: The specimen was utilized to evaluate the gene-disease condition, which included whole blood, serum, tumor tissue, etc.
6. Diseases: Included a list of disease conditions for which the genetic test was utilized
7. Clinical uses: Included genetic test applications in a clinical setting (e.g. routine use, investigational use, etc.).
8. Source: A list of additional sources that were typically consulted for information about the genetic test application.
9. Marker (Medline Search Terms): A PubMed search parameter; included the list of possible genetic test names, genes, and biomarkers that were used for Medline search strategy.
10. Organ (Medline Search Terms): A PubMed search parameter; included a list of specific organ(s) affected by the gene-disease association.
11. Exploratory PubMed search: The exploratory PubMed search included the name of the genetic or molecular marker, the disease, and the terms “cancer condition [MeSH®]”. For tests that use a panel of genetic or molecular markers, we used the brand name of the panel crossed with the search terms. All searches were repeated on 1/01/2011. These search strategies are exploratory and the number of citations returned is an estimate of the scientific literature available on each test-disease condition. However, this number is preliminary and would be subject to change from the use of a more fully developed search strategy and the application of specific screening criteria.

## Description of the electronic database

We developed an in-house electronic database for efficient storage and retrieval of the aforementioned information on eligible genetic tests. For convenience, we developed a user-friendly front end (interface) that allows browsing and searching of the database without the need to use low-level programming commands.

### MySQL database

We have created a My Structured Query Language (MySQL) (http://www.mysql.com/) database to store the collected genetic test information. MySQL is a relational database management system that is free, open-source, well documented, extremely robust, and widely used. It is often held to be a de facto standard for databases. Furthermore, the embedded SQL query language allows for quick and flexible querying of the stored data. For example, the end user can easily request information for all tests related to a specific cancer, with an arbitrarily complex set of limits. MySQL databases can be exported to a myriad of other formats, including Microsoft© Excel readable Comma Separated Values (CSV) format.

In the genetic test database, data is separated into cancer and non-cancer genetic tests. For each, we kept a record of all the data needed for one-page summaries of genetic tests. In particular, for cancer-related genetic tests, the used fields corresponded to the items described in the “Individual test summaries” section.

### Front end

The MySQL database created for this review stores and indexes all of the genetic tests. However, it is not necessarily straightforward for those unfamiliar with MySQL (and the SQL query language), limiting access to this data once collected. The Tufts-EPC is therefore developing a user-friendly interface to interact with the database, dubbed the ‘GeneTestTracker.’ The front end is Web-based, and written in the Python programming language (http://python.org/), using the Pylons (http://pylonshq.com/) Web framework. Having a Web-based program is advantageous because it theoretically allows remote access to the database (via any standard internet browser), is platform independent, and software updates need only be dropped on to the server (rather than installed manually by end users).

Upon logging in to the password-protected site, users can see all of the genetic tests in a tabular format; the non-cancer tests are displayed on one tabbed page, while the cancer tests are displayed in Figure 1. From this screen, users can add a new genetic test by simply clicking the “add new” button. Furthermore, users can click on an existing gene test to bring up the corresponding one-page summary. This summary can then be edited or deleted by the user. Additionally, a Microsoft© Word-friendly Rich Text Format (RTF) document can be automatically generated from the summary page, which the user can download to their computer locally, or print out. We have also interfaced with PubMed so as to automatically generate the number of hits a search in PubMed turns up for a gene test over time.

### Updating of the database

The horizon scanning has been ongoing as a continuous process since 2007 and the database is being continuously updated. The results of grey literature along with one-pagers are sent to AHRQ quarterly. The relevance of the genetic tests and their evolution are assessed biannually. In the results section, we describe more on the evolution of previously identified genetic tests for cancer conditions.

Figure 1 The front end to GeneTestTracker, the electronic database that lists genetic and genomic tests

Figure 1 (page 14) is a snapshot of Gene Test Tracker, the front end to the electronic database that lists genetic and genomic tests. After logging in the password-protected site, the user sees an html page depicting a table. Each row pertains to a specific test. The columns list the test name, gene symbol, protein name, test name, non-cancer condition and description of disease, purpose of the test, availability, specimen, methodology, clinical use, sources, marker, organ, PubMed search strategies, the number of PubMed hits, the date of update, and FDA approval status for the test. Above the columns is a search window where the user may search the database for any genetic test within two categories, cancer and non-cancer. The database may be searched using the test name, gene symbol, disease, or laboratory as keywords to find a specific test or any number of tests currently available for a specific disease.

Figure 1 is a snapshot of Gene Test Tracker, the front end to the electronic database that lists genetic and genomic tests. After logging in the password-protected site, the user sees an html page depicting a table. Each row pertains to a specific test. The columns list the test name, cancer and description of disease, purpose of the test, availability, specimen, methodology, clinical use, sources, marker, organ, and PubMed search strategies. Above the columns is a search window in which the user may search the database for any genetic test within two categories, cancer and non-cancer. The database may be searched using the test name, gene symbol, disease, or laboratory as keywords to find a specific test or any number of tests currently available for a specific disease.