# Discussion

We performed Internet-based grey literature searches and added 50 new genetic tests available for clinical use in cancer conditions. Of these, 16 tests were identified through internet searches alone, 21 tests matured to clinical use of the 104 tests “in development” in our 2006 report; and 13 tests were identified by experts during the peer review process. Recent grey literature searches indicate that the largest numbers of new tests were found in the breast, colorectal, and multiple cancer categories. Most of the information for each of the genetic tests was gathered from various public and proprietary Web sites. The laboratories offering genetic testing services provided most of the information on the description of the gene involved with the disease. We searched sites that were identified from our 2006 horizon scan report, Genetic Testing for Cancer Conditions and many other sites identified through Google News searches. Our list encompasses both gene associations of potential biomarkers and pharmacogenomic tests using a broad definition of genetic tests put forth by the 2008 SACGHS Report. In terms of tests of gene associations, only few biomarkers ever make it to the clinical application stage. Thus, the list of tests we identified in this report along with genetic tests identified in our 2006 report are fairly comprehensive within the sources we evaluated for the disease-conditions and for the population of interest.

Potential limitations of our report include lack of empirical structure providing guidance on how to conduct optimal grey literature searches of the Internet. The following are caveats to our grey literature searches. Internet searches in Google are not strictly reproducible. This has been partially overcome by storing Web links along with access dates in our database. However, for searches conducted within a reasonably short time period, the Web pages will be more or less the same. To overcome such limitations related to searches conducted in Google, we supplemented Internet searches with periodic review of Web sites of major companies that manufacture genetic and molecular tests, and by searching the FDA Web site. The attempt to horizon scan genomic testing through Web searching has been applied by other groups.(4) When compared to our previous 2006 report, the methodology is different, in that recent horizon scanning rely only on Internet searching without further contact with the companies. Currently, this process limits our ability to identify a test with multiple commercial names (for example, a test that has been licensed from one company to another company, but carries a different commercial name for the same test) or if changes are made to a test that retains the same name (for example, when additional single-nucleotide polymorphisms are added to a test).

Our report indicates that there has been an increase in the number of genetic tests for specific common cancer conditions, and there is inherent subjectivity in identifying emerging genetic tests. Many genetic and molecular markers and panels are being associated with cancer conditions. We have selected those that are available for clinical applications in screening, diagnosis, prognosis, prediction, disease recurrence, therapeutic management, or patient monitoring as tests for cancer conditions. In addition to grey literature searches, our discussion with local experts as well as the external panel of reviewers helped us to identify this list of genetic tests.

This report of horizon scan for genetic tests for cancer conditions, with biannual updates, adds important information on emerging tests. Currently, there are attempts by different national agencies to summarize information on genetic tests.(4; 5) Until the NIH registry is fully effective, the current report is a valuable source of genetic tests that are in clinical use with specific applicability to older adults. Genetic testing is a rapidly emerging field with the potential to dramatically influence clinical decision-making. Health care providers, patients, payers, decision-makers, and consumers can benefit from staying abreast of newly-released tests.