# Tests that matured to clinical use since 2006

Name | Breast | Prostate | Lung | Colorectal | Pancreas | Ovarian | Esophagus | Liver | Lymphoma | Leukemia | Other
AFP-L3 | | | | | | | | x
BladderChek | | | | | | | | | | | x
CeMines CellCorrect Lab | | | x
c-Kit pharmDx | | | | | | | | | | | x
Colorectalert | | | | x
cPSA | | x
CupPrint | | | | | | | | | | | x
Cyfra 21-1 | | | x
DNA methylation (oncomethylome) | | x | x | | | x | | | | | x
DNA methylation (second code) | | x | x | x
EGFR | | | x
Immunocyt/uCyt | | | | | | | | | | | x
K-ras | | | x | x
MammaPrint | x
MESOMARK | | | | | | | | | | | x
MGMT | | | | x
NMP22 | | | | | | | | | | | x
Ovacheck | | | | | | x
Prostate 63 | | x
TUO test | | | | | | | | | | | x
uPM3 | | x