# One-page summaries of the genetic tests for cancers

## BREAST CANCER

### Gene Test Information: Breast Profile (TM), Breast

Test Name: Breast Profile (TM)

Description: Breast Profile (TM) identifies a patient’s HER2 status and in addition, can risk-stratify patients according to their cancer’s molecular subtype association (Luminal A, Luminal B, ERBB2, Basal, Unclassified) to aid in therapeutic management. The test evaluates the tumor’s overall genomic stability vs. instability for additional risk stratification of patients into Low vs. High Risk groups.

Purpose: Therapeutic management

Availability: CombiMatrix Diagnostics

Specimen: Paraffin-embedded tumor tissue block

Methodology: DNA array-based comparative genomic hybridization (aCGH) and molecular subtyping

Diseases: Breast

Clinical Uses: Detects HER2 gene status along with cancer’s molecular subtyping. The test identifies an independent marker of high risk disease and poor prognosis. The potential side effects of trastuzumab and response to treatment increase the importance of identifying HER2 gene and other molecular subtypes.

Sources: combimatrix.com

Marker (Medline Search Terms): (array-comparative genomic hybridization OR DNA copy number alteration)

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND (array-comparative genomic hybridization OR DNA copy number alteration) AND Breast

Medline hits=521.

FDA Approved: No

### Gene Test Information: deCODE BreastCancer, Breast cancer

Test Name: deCODE BreastCancer

Description: The deCODE BreastCancer test determines the genotypes for 7 known single-nucleotide polymorphisms (SNPs) that have been linked to genetic predisposition to female breast cancer. The variants are located on chromosomes 2q35 (rs13387042), 5p12 (rs4415084, near the MRPS30 gene), 5q11 (rs889312, near the MAP3K1 gene), 8q24 (rs13281615), 10q26 (rs1219648, near the FGFR2 gene), 11p15 (rs3817198, near the LSP1 gene), and 16q12 (rs3803662, near the TNRC9 TOX3 gene). Based on an individual’s genotypes for these SNP markers, lifetime genetic risk of being diagnosed with breast cancer can be determined and related to the general risk of breast cancer in the population.

Purpose: Prognostic predictive, diagnostic

Availability: deCODE diagnostics

Specimen: Blood, buccal

Methodology: ND

Diseases: Breast cancer

Clinical Uses: The test may indicate a use for preventative therapy. The test is also useful in parallel with BRCA1 and BRCA2 testing since it may reinforce that patients who are negative for BRCA1 and BRCA2 may still be at increased risk for later-onset breast cancer.

Sources: deCODE diagnostics

Marker (Medline Search Terms): rs13387042 OR rs4415084 OR rs889312 OR rs13281615 OR rs1219648 OR rs3817198 OR rs3803662

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND rs13387042 OR rs4415084 OR rs889312 OR rs13281615 OR rs1219648 OR rs3817198 OR rs3803662 AND Breast

Medline hits=38.

FDA Approved: No

### Gene Test Information: GeneSearch BLN Assay, Metastatic Breast cancer

Test Name: GeneSearch BLN Assay

Description: The assay detects the presence of breast tissue in nodal tissue using two tissue specific RNA molecules as biomarkers. The two biomarker RNAs are transcribed from genes expressed at high levels in breast cancer tissue but only at low or background levels in nodal tissue.

Purpose: Prognostic, Predictive, Diagnostic

Availability: Commercial labs and Academic hospitals

Specimen: Sentinel lymphnode

Methodology: reverse transcriptase polymerase chain reaction assay

Diseases: Metastatic Breast cancer

Clinical Uses: During a lumpectomy or mastectomy to remove a breast tumor, surgeons commonly remove the sentinel node for examination under a microscope. Results of this rapid test are available while patients are on the operating table, helps to avoid a second operation.

Sources: FDA, Veridex

Marker (Medline Search Terms): GeneSearch BLN Assay

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND GeneSearch BLN Assay AND Breast

Medline hits=8.

FDA Approved: Yes

### Gene Test Information: Her2 neu overexpression, Breast cancer

Test Name: Her2 neu overexpression

Description: HER2 neu (also known as ErbB-2, ERBB2) stands for "Human Epidermal growth factor Receptor 2" and is a protein giving higher aggressiveness in breast cancers. It is a member of the ErbB protein family, more commonly known as the epidermal growth factor receptor family. HER2 neu has also been designated as CD340 (cluster of differentiation 340) and p185. Because anti-HER2 neu therapy benefits only patients with invasive breast carcinomas overexpressing HER2 neu, testing is used to identify those patients most likely to respond to anti-HER2 neu therapies.

Purpose: Therapeutic management

Availability: Commercial laboratories, including HercepTest (Dako Corp, Carpinteria, Calif), Subsequently Pathway (Ventana Medical Systems, Tucson, Ariz), Her2 Pro (TM) from Combimatrix

Specimen: Tumor tissue

Methodology: Molecular: PCR, FISH, Northern blot, or protein overexpression via ELISA, Western blot on cytosols or IHC

Diseases: Breast cancer

Clinical Uses: The potential side effects of Herceptin and the cost of therapy increase the importance of identifying HER2 neu overexpression. Given the latter considerations and the fact that the majority of patients with carcinoma overexpressing HER2 neu do not benefit from trastuzumab, testing may also be conceptualized as a mode of selecting patients who lack HER2 neu overexpression and thus should not be treated with Herceptin.

Sources: www.medscape.com

Marker (Medline Search Terms): Trastuzumab AND HER2 neu

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND Trastuzumab AND HER2 neu AND Breast

Medline hits=264.

FDA Approved: Yes

### Gene Test Information: HER2 Pro(TM), Breast

Test Name: HER2 Pro(TM)

Description: HER2 Pro (TM) identifies a patient’s genomic copy number changes at the DNA level. The test evaluates a complete genomic analysis of each patient’s unique tumor DNA. Every breast cancer has a unique genomic aberration pattern that is associated with distinct prognostic and therapeutic characteristics. Genomic subtyping of the patient’s tumor can provide significant value in the overall treatment planning and also provide additive risk assessment measures to conventional testing.

Purpose: Diagnostic, therapeutic management

Availability: CombiMatrix Diagnostics

Specimen: Paraffin-embedded tissue block, non-fragmented total DNA

Methodology: DNA array-based comparative genomic hybridization (aCGH)

Diseases: Breast

Clinical Uses: The DNA array-based karyotyping detects aneusomy of chromosome 17, which is proven to be an independent marker of high risk disease and poor prognosis. The potential side effects of trastuzumab and response to treatment increase the importance of identifying HER2 gene status.

Sources: combimatrix.com

Marker (Medline Search Terms): Array-based karyotyping OR Her2 Pro

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND (Array-based karyotyping OR Her2 Pro) AND Breast

Medline hits=3.

FDA Approved: No

### Gene Test Information: MammaPrint(R), Breast cancer

Test Name: MammaPrint(R)

Description: The MammaPrint test uses molecular technology to predict whether existing cancer will metastasize (spread to other parts of a patient’s body). The MammaPrint test measures the level of activity of each of these genes in a sample of surgically removed breast cancer tumor, then uses a specific formula, known as an algorithm, to produce a score that determines whether the patient is deemed low risk or high risk for spread of the cancer to another site.

Purpose: Prognostic predictive, diagnostic

Availability: Commercial laboratories

Specimen: Breast tissue

Methodology: Molecular: microarray analysis

Diseases: Breast cancer

Clinical Uses: Prognostic tests like the MammaPrint can measure the activity of genes, and thus help physicians understand their patient’s odds of the cancer spreading.

Sources: FDA, Agendia

Marker (Medline Search Terms): MammaPrint

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND MammaPrint AND Breast

Medline hits=40.

FDA Approved: Yes

### Gene Test Information: SPOT-Light (R) HER2 CISH Kit, Breast cancer

Test Name: SPOT-Light (R) HER2 CISH Kit

Description: Patients with breast cancer may have more copies of HER2 gene, prompting them to overproduce HER2 protein so that more signals are sent to breast cells. As a result, the cells grow and divide much too quickly. This gene regulates the growth of cancer cells. The SPOT-Light HER2 CISH kit is a test that measures the number of copies of the HER2 gene in tumor tissue.

Purpose: Therapeutic management

Availability: Invitrogen

Specimen: Tumor tissue from breast

Methodology: Chromogenic in situ hybridization (CISH)

Diseases: Breast cancer

Clinical Uses: SPOT-Light HER2 CISH kit is a genetic test for determining whether patients with breast cancer are good candidates for treatment with the drug Herceptin (trastuzumab)

Sources: www.invitrogen.com; www.FDA.gov

Marker (Medline Search Terms): HER2 CISH

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND HER2 CISH AND Breast

Medline hits=67.

FDA Approved: Yes

### Gene Test Information: Tamoxitest, Breast

Test Name: Tamoxitest

Description: About 7–10% of women with breast cancer may not receive the full medical benefit from taking tamoxifen due to having a version of Cytochrome P450 2D6 (CYP2D6) which reduces the effectiveness of tamoxifen and increases their chance of breast cancer recurrence.

Purpose: Therapeutic management

Availability: Genelex and other commercial laboratories

Specimen: Buccal swab

Methodology: ND

Diseases: Breast

Clinical Uses: The CYP2D6 test for tamoxifen is considered appropriate for women who are taking or considering taking tamoxifen to prevent the recurrence of breast cancer. It is especially important if the patient is also taking or considering co-administration with SSRIs.

Sources: www.Genelex.com

Marker (Medline Search Terms): Cytochrome P-450 OR CYP2D6

Organ (Medline Search Terms): Tamoxifen

Medline Searches: neoplasm AND Cytochrome P-450 OR CYP2D6 AND Tamoxifen

Medline hits=351.

FDA Approved: No

### Gene Test Information: TOP2A FISH pharmDx, Breast cancer

Test Name: TOP2A FISH pharmDx

Description: The TOP2A gene plays a role in DNA replication. The TOP2A FISH pharmDx test uses fluorescently labeled DNA probes to detect or confirm gene or chromosome abnormalities. The recurrence of cancer depends partly on certain genes whose activity may be altered by changes in the number of gene copies in the tumor. Changes in the TOP2A gene in breast cancer cells mean there is an increased likelihood that the tumor will recur or that long-term survival will be decreased.

Purpose: Prognostic predictive, monitoring

Availability: Dako

Specimen: Tumor tissue

Methodology: Fluorescent in situ hybridization (FISH)

Diseases: Breast cancer

Clinical Uses: The test helps in assessing the risk of tumor recurrence and long-term survival for patients with relatively high-risk breast cancer.

Sources: www.FDA.gov; www.dako.com

Marker (Medline Search Terms): TOP2A or (Topoisomerase 2A)

Organ (Medline Search Terms): Breast

Medline Searches: neoplasm AND (TOP2A or topoisomerase 2A) AND Breast

Medline hits=87.

FDA Approved: yes

## COLORECTAL CANCER

### Gene Test Information: BRAF Mutation Test, Colorectal cancer

Test Name: BRAF Mutation Test

Description: In colorectal adenocarcinomas and in certain other cancers, BRAF V600E acts as an oncogene driving tumor cell proliferation. Patients whose colon cancer harbored BRAF mutation had poor response to anti-EGFR therapy (e.g. panitumumab or cetuximab). BRAF mutation is found in about 14% of KRAS wild type cancers. Patients whose colon cancer harbors BRAF mutation also have a worse prognosis based on time to progression and survival data, especially when the cancer is microsatellite stable (MSS).

Purpose: Diagnosis, Prognosis, therapeutic management

Availability: Academic and Commercial laboratories

Specimen: Paraffin block of tumor cells

Methodology: Molecular: PCR

Diseases: Colorectal cancer

Clinical Uses: Useful in patients with colorectal adenocarcinoma and absent KRAS mutation, who are candidate for anti-EGFR therapy. Also is useful in the work-up of Lynch syndrome in patients with colorectal carcinomas who are having microsatellite instability (MSI-H) or loss of MLH1 protein expression.

Sources: www.unchealthcare.org; www.genzymegenetics.com

Marker (Medline Search Terms): BRAF mutation

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND BRAF mutation AND colorectal

Medline hits=365.

FDA Approved: No

### Gene Test Information: Colopath(R) or ColorectAlert(TM), Colorectal cancer

Test Name: Colopath(R) or ColorectAlert(TM)

Description: Colopath(R) screens for a phospholipid analyte (plasmalogen) in rectal mucus of individuals with colorectal pathology, whereas ColorectAlert(TM) screens for the T-antigen, a complex sugar in rectal mucus. Both tests involve the application of a rectal mucus sample to a test strip and a positive negative result is based on a Schiffs aldehyde reaction.

Purpose: Diagnostic

Availability: Commercial labs

Specimen: Rectal mucus

Methodology: not documented

Diseases: Colorectal cancer

Clinical Uses: Highly sensitive and minimally invasive screening and monitoring test strip for colorectal cancer.

Sources: Procyon Biopharma Inc., www.ambriliabiopharma.com

Marker (Medline Search Terms): (plasmalogen or colopath or colorectAlert)

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND (plasmalogen or colopath or colorectAlert) AND colorectal

Medline hits=1.

FDA Approved: No

### Gene Test Information: ColonSentry(TM), Colorectal cancer

Test Name: ColonSentry(TM)

Description: The ColonSentry(TM) test measures the expression of seven genes in whole blood, which serve as biomarkers to detect colorectal cancer.

Purpose: Primary prevention

Availability: GeneNews(TM) Corporation

Specimen: Whole blood

Methodology: Microarray and quantitative RT-PCR (qRT-PCR)

Diseases: Colorectal cancer

Clinical Uses: The ColonSentry test is a risk stratification tool that will enable better physician-patient dialogue and decisionmaking as part of the colorectal cancer screening process.

Sources: ColonSentry (www.colonsentry.com)

Marker (Medline Search Terms): (genes and biological markers)

Organ (Medline Search Terms): colorectal

Medline Searches: neoplasm AND (genes and biological markers) AND colorectal

Medline hits = 1122

FDA Approved: No

### Gene Test Information: Cytokeratin 20 (CK20), Colorectal and gastrointestinal carcinomas

Test Name: Cytokeratin 20 (CK20)

Description: Cytokeratin 20 is 46 kDa intermediate filament protein that has been identified with expression primarily restricted to gastric and intestinal epithelium, urothelium, and Merkel cells. Cytokeratin 20 is a unique type I keratin that is expressed in adenocarcinomas of the colon, stomach, pancreas and bile system. It is also expressed in mucinous ovarian tumors, transitional cell carcinomas of the urinary tract, and Merkel cell carcinomas. CK20 is essentially non-reactive in squamous cell carcinomas and adenocarcinomas of the breast, lung, and endometrium, as well as non-mucinous tumors of the ovary and small cell carcinomas. CK20 was formerly known as "protein IT".

Purpose: Diagnostic

Availability: Commercial Laboratories

Specimen: Tumor tissue

Methodology: Immunohistochemistry

Diseases: Colorectal and gastrointestinal carcinomas

Clinical Uses: Cytokeratin 20 is often used in conjunction with CK7 and other antibodies in distinguishing colon carcinomas (CK20+) from ovarian, pulmonary, and breast carcinomas.

Sources: Biocare Medical

Marker (Medline Search Terms): Cytokeratin 20 or CK20

Organ (Medline Search Terms): Colorectal

Medline Searches: neoplasm AND (Cytokeratin 20 or CK20) AND Colorectal

Medline hits=266.

FDA Approved: No

### Gene Test Information: KRAS mutation analysis, Colorectal cancer

Test Name: KRAS mutation analysis

Description: Individuals respond differently to chemotherapeutic and targeted biologic agents. The evaluation of therapeutic markers, such as KRAS can help patients individualize cancer therapy for their patients. Recent studies have shown that assessing KRAS gene mutational status in tumor tissue can help identify patients who may not benefit from cetusimab or panitumab treatment.

Purpose: Prognostic Predictive

Availability: Genzyme genetics; other Commercial Labs

Specimen: Tumor tissue

Methodology: Single nucleotide primer extension

Diseases: Colorectal cancer

Clinical Uses: KRAS Mutation Analysis provides additional guidance in therapeutic treatment decisions for patients with metastatic colorectal cancer.

Sources: Commercial Labs

Marker (Medline Search Terms): Codons 12 and 13 of the KRAS gene

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND Codons 12 and 13 of the KRAS gene AND Colon

Medline hits=8.

FDA Approved: No

### Gene Test Information: Oncotype DX(R) colon cancer assay, Colon cancer

Test Name: Oncotype DX(R) colon cancer assay

Description: The Oncotype DX Colon Cancer Assay is clinically available for patients with newly diagnosed stage II colon cancer. The Oncotype DX Colon Cancer Assay is a clinically validated diagnostic assay based on an individual patient’s colon tumor expression of 12 genes (seven cancer-related, five reference), which quantifies the likelihood of recurrence in stage II colon cancer in the three years following surgery. This test provides physicians with a precise assessment of the underlying tumor biology for this gene panel, and provides value beyond currently available clinical and pathological tools to quantify the risk of recurrence for each individual patient. Use of this test allows clinicians and patients to make more appropriate decisions regarding adjuvant chemotherapy, which will help maximize the benefits of treatment while minimizing the risk.

Purpose: Prognosis

Availability: Genomic Health, Inc.

Specimen: Paraffin-embedded breast tumor tissue

Methodology: RT-PCR

Diseases: Colon cancer

Clinical Uses: Oncotype DX is a prognostic assay that assesses the likelihood of cancer recurrence.

Sources: www.genomichealth.com

Marker (Medline Search Terms): Oncotype DX

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND Oncotype DX AND colon

Medline hits = 3

FDA Approved: Yes

### Gene Test Information: Septin 9 DNA methylation biomarker, Colorectal center

Test Name: Septin 9 DNA methylation biomarker

Description: This test is a molecular-based laboratory test that can help physicians detect colorectal cancer based on a patients blood specimen. This technology aims at detecting DNA based on specific DNA methylation patterns in blood plasma samples or other body fluids. The Septin 9 gene encodes a protein involved in cell division and is thought to play a role in the onset of cancer.

Purpose: Diagnostic

Availability: Epigenomics, Quest Diagnostics

Specimen: Blood

Methodology: Portfolio of proprietary DNA methylation technologies and biomarkers

Diseases: Colorectal center

Clinical Uses: The Septin 9 DNA methylation test acts as a supplement to conventional methods of colorectal cancerscreening, including colonoscopy and fecal occult blood tests (FOBTs)

Sources: www.epigenomics.com

Marker (Medline Search Terms): DNA methylation

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND DNA methylation AND Colon

Medline hits=774.

FDA Approved: No

### Gene Test Information: UGT1A1 Molecular Assay(TM), Colorectal cancer

Test Name: UGT1A1 Molecular Assay(TM)

Description: The UGT1A1 Molecular Assay is an in-vitro diagnostic test that detects two genetic polymorphisms in the UGT1A1 gene. The enzyme produced by UGT1A1 is responsible for the metabolism of irinotecan (Camptosar), a drug used in combination with standard chemotherapeutic agents in the first-line treatment of patients with metastatic colorectal cancer. The UGT1A1 Molecular Assay detects the *1 (TA6) and *28 (TA7) alleles of the UGT1A1 gene in genomic DNA. This test will help identify patients with a greater risk for irinotecan toxicity.

Purpose: Recurrence

Availability: Genzyme Genetics; other commercial labs

Specimen: Blood

Methodology: In vitro nucleic acid hybridization assay

Diseases: Colorectal cancer

Clinical Uses: The assay identifies patients with specific genetic mutations that have been associated with an increased risk of neutropenia after use of Camptosar (irinotecan), the antineoplastic agent used to treat metastatic colorectal cancer. The active form of irinotecan is metabolized by the polymorphic enzyme UGT1A1. UGT1A1 activity is reduced in individuals with genetic polymorphisms that lead to reduced enzyme activity, such as the UGT1A1*28 polymorphism. Approximately 10% of the North American population is homozygous for the UGT1A1*28 allele. Patients with reduced UGT1A1 activity are at an increased risk of experiencing grade 4 neutropenia when treated with irinotecan.

Sources: FDA insert: http://www.ons.org/fda/documents/FDA93005insert.pdf.

Marker (Medline Search Terms): UGT1A1

Organ (Medline Search Terms): Colon

Medline Searches: neoplasm AND UGT1A1 AND Colon

Medline hits=20.

FDA Approved: No

## GENITOURINARY

### Gene Test Information: ImmunoCyt™/uCyt+™, Bladder cancer

Test Name: ImmunoCyt™/uCyt+

Description: ImmunoCyt™/uCyt+ uses a cocktail of 3 monoclonal antibodies to detect bladder cancer cells in the urine. When combined with routine cytology, the detection rate for bladder cancer is high.

Purpose: Monitoring of recurrent bladder cancer

Availability: Commercial Labs

Specimen: Urine

Methodology: Immunocytofluorescence

Diseases: Bladder cancer

Clinical Uses: Combines immunofluorescence method with morphological evaluation via urine cytology provides a noninvasive, highly sensitive tool for the early detection of bladder cancer recurrence. The ImmunoCyt™ test detected low-grade as well as high-grade cancers with a sensitivity ranging from 60% to 76%. Combining the two tests increases the sensitivity to over 80% for high-grade cancers and 67% for low-grade cancers.

Sources: scimedx.com

Marker (Medline Search Terms): Immunocyt

Organ (Medline Search Terms): Bladder

Medline Searches: neoplasm AND Immunocyt AND Bladder cancer

Medline hits=29.

FDA Approved: Yes

### Gene Test Information: NMP22(R) test kit or NMP22(R)BladderChek(R), Bladder cancer

Test Name: NMP22(R) test kit or NMP22(R)BladderChek(R)

Description: Test detects elevated levels of NMP22 protein. Healthy individuals generally have very small amounts of NMP22 protein in the urine. However, the level of NMP22 protein is often elevated in the urine of patients with bladder cancer, even at early stages of the disease.

Purpose: Diagnostic

Availability: Commercial laboratories and academic laboratories

Specimen: Urine

Methodology: microplate enzyme immunoassay

Diseases: Bladder cancer

Clinical Uses: The test is a quantitative tool that identifies hidden or rapidly recurring disease. The test can be performed in a physician’s office with results delivered during the patient visit, allowing a rapid, accurate and cost-effective way to aid in the detection of bladder cancer in patients at risk.

Sources: www.matritech.com, Wampole Laboratories, FDA

Marker (Medline Search Terms): NMP22

Organ (Medline Search Terms): Bladder

Medline Searches: neoplasm AND NMP22 AND Bladder

Medline hits=187.

FDA Approved: Yes

## HEMATOLOGICAL

### Gene Test Information: G6PD deficiency, Hematologic cancers

Test Name: G6PD deficiency

Description: Rasburicase has recently been approved for the management of reduction of uric acid due to tumor lysis syndrome in hematologic malignancies. Patients with glucose-6-phosphate dehydrogenase (G6PD) deficiency who are treated with rasburicase are at risk of severe hemolysis. Rasburicase is contraindicated for such patients. Patients deficient in G6PD have reduced ability to reduce the hydrogen peroxide formed as a major byproduct of the rasburicase-catalyzed oxidation of uric acid to allantoin.

Purpose: Therapeutic management

Availability: Commercial laboratories

Specimen: Blood

Methodology: Direct DNA testing and or sequencing of the G6PD gene

Diseases: Hematologic cancers

Clinical Uses: The FDA recommends, but does not require, genetic testing prior to initiating treatment with rasburicase. It is recommended that patients at higher risk for G6PD deficiency (e.g., patients of African or Mediterranean ancestry) be screened prior to starting rasburicase therapy.

Sources: PharmGKB

Marker (Medline Search Terms): Glucose-6-phosphate dehydrogenase

Organ (Medline Search Terms): Blood

Medline Searches: neoplasm AND Glucose-6-phosphate dehydrogenase AND Rasburicase

Medline hits=5.

FDA Approved: No

### Gene Test Information: Heme Profile (TM), Hematological

Test Name: Heme Profile (TM)

Description: This is a DNA array-based test for detecting chronic lymphocytic leukemia (CLL) and myelodysplastic syndromes. Since tumor burden is high in the peripheral blood, CLL can be evaluated with array-based karyotyping that also detects 11q deletion. Heme Profile combines the high resolution of FISH with the genome-wide copy number assessment found in traditional cytogenetics testing.

Purpose: Prognostic

Availability: Combimatrix

Specimen: Blood or bone marrow

Methodology: Microarray and FISH analysis

Diseases: Hematological

Clinical Uses: The test delineates key genome-wide gains and losses, which equates detailed prognostic portrait of patient’s tumor. It aids in monitoring for clonal evolution and disease progression.

Sources: Combimatrix.com

Marker (Medline Search Terms): array-comparative genomic hybridization

Organ (Medline Search Terms): Leukemia

Medline Searches: neoplasm AND array-comparative genomic hybridization AND Leukemia

Medline hits=390.

FDA Approved: No

### Gene Test Information: JAK2, Chronic myeloproliferative disorder

Test Name: JAK2

Description: The JAK2 V617F mutation is specifically associated with chronic myeloproliferative disorders. It has been reported in approximately 97% of polycythemia vera, 57% of essential thrombocythemia and 50% chronic idiopathic myelofibrosis.

Purpose: Diagnosis, Therapeutic Management

Availability: Academic, commercial laboratories

Specimen: Bone marrow or blood

Methodology: Polymerase chain reaction (PCR), gel electrophoresis

Diseases: Chronic myeloproliferative disorder

Clinical Uses: Confirms diagnosis in individuals with clinical suspicion of myloproliferative disorders.

Sources: www.ohsu.edu pathology wardman forms jak2infosheet.pdf, www.genzymegenetics.com

Marker (Medline Search Terms): JAK2

Organ (Medline Search Terms): myeloproliferative disorder

Medline Searches: neoplasm AND JAK2 AND myeloproliferative disorder

Medline hits=421.

FDA Approved: No

### Gene Test Information: KIT Asp816Val Mutation Analysis, Resistance to Imatinib therapy in chronic myeloid leukemia

Test Name: KIT Asp816Val Mutation Analysis

Description: Imatinib is an inhibitor of the BCR-ABL tyrosine kinase that is created by the Philadelphia chromosome rearrangement in chronic myeloid leukemia. Imatinib also inhibits the kinases encoded by the PDGFRB and KIT genes. The KIT:D816V mutation, found in many patients with aggressive systemic mastocytosis is associated with resistance to treatment with imatinib.

Purpose: Diagnostic, therapeutic management

Availability: Commercial labs

Specimen: Bone marrow; whole blood

Methodology: Allele-specific oligonucleotide polymerase chain reaction (ASO-PCR) with fragment analysis

Diseases: Resistance to Imatinib therapy in chronic myeloid leukemia

Clinical Uses: Aids with diagnosing systemic mastocytosis and guiding imatinib therapy in chronic myeloid leukemia.

Sources: PharmGKb; Mayo medical Lab

Marker (Medline Search Terms): KIT Asp816Val

Organ (Medline Search Terms): Imatinib

Medline Searches: neoplasm AND KIT Asp816Val AND Imatinib

Medline hits=4.

FDA Approved: No

## Lung

### Gene Test Information: CellCorrect KvA-40 Cell Correct Lab clinical Dx, Lung cancer

Test Name: CellCorrect KvA-40 Cell Correct Lab Clinical Dx

Description: The test uses a bioinformatics platform, with a profiling library of more than 1500 key biomarkers and an additional 700 biomarkers that may be relevant in determining certain characteristics related to the reproduction stage of cancer cells.

Purpose: Diagnosis

Availability: Commercial labs

Specimen: Whole blood

Methodology: Molecular finger printing

Diseases: Lung cancer

Clinical Uses: The test detects molecular fingerprints of disease-related autoantibodies in the bloodstream. Currently, the test is utilized for lung cancer diagnosis. Other potential applications include the detection and diagnosis of breast, colon, and stomach cancer.

Sources: www.medscape.com, CeMines, Inc

Marker (Medline Search Terms): Molecular fingerprinting

Organ (Medline Search Terms): Lung

Medline Searches: neoplasm AND Molecular fingerprinting AND Lung

Medline hits=32.

FDA Approved: No

### Gene Test Information: EGFR Mutation Analysis, Non-Small Cell Lung Cancer

Test Name: EGFR Mutation Analysis

Description: Epidermal growth factor receptor (EGFR) mutation analysis detects EGFR gene mutations in tumor specimens of patients with non-small cell lung cancer (NSCLC) using microdissection of tumor tissue. EGFR, when activated, plays a role in cellular tumor growth and proliferation and is the target of tyrosine kinase inhibitors (TKI). Clinical studies have found that up to 20% of NSCLC tumors harbor the EGFR mutation, and that ~85% of patients with these mutations respond to TKI treatment. The molecular diagnostic procedure incorporates PCR amplification and bidirectional gene sequencing of exons 18 through 21 of the tyrosine kinase domain of the EGFR gene.

Purpose: Therapeutic management

Availability: www.genzymegenetics.com

Specimen: Tumor tissue

Methodology: Molecular: DNA sequencing

Diseases: Non-Small Cell Lung Cancer

Clinical Uses: To guide the use of EGFR-targeted tyrosine kinase inhibitor (TKI) therapy.

Sources: www.genzymegenetics.com

Marker (Medline Search Terms): (EGFR gene OR erbb-1 genes)

Organ (Medline Search Terms): Non-Small Cell Lung Cancer

Medline Searches: neoplasm AND (EGFR gene OR erbb-1 genes) AND Non-Small Cell Lung Cancer

Medline hits=736.

FDA Approved: No

### Gene Test Information: ELSA-CYFRA 21-1, Non-small cell lung cancer

Test Name: ELSA-CYFRA 21-1

Description: CYFRA 21-1 is a cytokeratin 19 fragment found in serum of cancer patients. Precise recognition of this fragment is made with two monoclonal antibodies (BM 19-21 and KS 19-1)* which were obtained after immunisation of mice with MCF-7 cells. Cytokeratin 19 (CK19) is a member of the intermediate filament group of proteins, whose physiological role remains unclear.

Purpose: Prognostic, prognostic predictive

Availability: Cisbio Bioassays

Specimen: Serum

Methodology: Solid-phase sandwich immunoradiometric assay

Diseases: Non-small cell lung caner

Clinical Uses: Preliminary clinical studies of bronchial cancer patients sera have shown that CYFRA 21-1 assay is useful in the diagnosis and follow-up of non-small cell lung carcinoma and particularly of squamous cell carcinoma of the lung.

Sources: Cisbio Bioassays

Marker (Medline Search Terms): Antigen CYFRA21.1

Organ (Medline Search Terms): Lung

Medline Searches: neoplasm AND Antigen CYFRA21.1 AND Lung

Medline hits=200.

FDA Approved: No

### Gene Test Information: ERCC1, Non-Small Cell Lung Cancer

Test Name: ERCC1

Description: The ERCC1 (Excision Repair Cross-Complementing Rodent Repair Deficiency, Complementation Group 1) polypeptide is required for nucleotide excision repair (NER) of damaged DNA. Elevated levels have also been reported in cisplatin-resistant cells.

Purpose: Therapeutic management

Availability: Commercial laboratories

Specimen: Formalin-fixed paraffin-embedded tumor tissue samples

Methodology: Immunohistochemical staining

Diseases: Non-Small Cell Lung Cancer

Clinical Uses: ERCC1 may guide the use of plantinum-based (for e.g., cisplatin or oxaliplatin) therapy.

Sources: www.clarientinc.com; www.genzymegenetics.com

Marker (Medline Search Terms): ERCC1

Organ (Medline Search Terms): Non-Small Cell AND Lung

Medline Searches: neoplasm AND ERCC1 AND Non-Small Cell AND Lung

Medline hits=161.

FDA Approved: No

### Gene Test Information: KRAS Mutation Analysis, Non-Small Cell Lung Cancer (NSCLC)

Test Name: KRAS Mutation Analysis

Description: Mutations with KRAS gene have been associated with poor prognosis, are reported in approximately 15–30% of lung carcinoma, and are associated with resistance to tyrosin kinase inhibitor treatment. KRAS Mutation Analysis analyzes codons 12 and 13 of the KRAS gene by allele-specific primer extension.

Purpose: Diagnostic, prognostic, predictive, and therapeutic management

Availability: www.Genzymegenetics.com

Specimen: Tumor tissue in fixed paraffin block with corresponding H&E slide

Methodology: Molecular:Allele-specific primer extension

Diseases: Non-Small Cell Lung Cancer (NSCLC)

Clinical Uses: The determination of KRAS mutational status of a tumor may guide therapeutic decision making for patients with NSCLC and aid in prognosis.

Sources: www.Genzymegenetics.com

Marker (Medline Search Terms): KRAS mutations or RAS oncogene

Organ (Medline Search Terms): Lung

Medline Searches: neoplasm AND (KRAS mutations or RAS oncogene) AND Lung

Medline hits=2015.

FDA Approved: No

### Gene Test Information: MESOMARK (R), Mesothelioma

Test Name: MESOMARK (R)

Description: The test measures soluble mesothelin related peptides in serum that may aid in the management of patients diagnosed with epithelioid or biphasic mesothelioma. Epidemiologic studies have established exposure to asbestos fibers as the primary cause of malignant mesothelioma.

Purpose: Diagnosis and therapeutic management

Availability: Arup Laboratory

Specimen: Blood (serum, plasma, or whole)

Methodology: Enzyme-Linked Immunosorbent Assay

Diseases: Mesothelioma

Clinical Uses: The test can aid in the management of patients diagnosed with epithelioid or biphasic mesothelioma.

Sources: www.aruplab.com

Marker (Medline Search Terms): Mesothelin

Organ (Medline Search Terms): Mesothelioma

Medline Searches: neoplasm AND mesothelin AND mesothelioma

Medline hits=125.

FDA Approved: Yes

## OVARIAN

### Gene Test Information: OVA1, Ovarian

Test Name: OVA1

Description: OVA1 uses a blood sample to test for levels of five proteins that change because of ovarian cancer. OVA1 then uses proprietary computer software to calculate a single numerical score based on the five protein levels. The test combines the five separate results into a single numerical score between 0 and 10 to indicate the likelihood that the pelvic mass is benign or malignant.

Purpose: Secondary prevention, Prognostic predictive

Availability: Commercial labs

Specimen: Blood

Methodology: ND

Diseases: Ovarian

Clinical Uses: OVA1 is the first FDA-cleared lab test for ovarian cancer that can indicate before biopsy or exploratory surgery, the likelihood of a highly sensitive cancer. The OVA1 test identifies some women who will benefit from referral to a gynecological oncologist for their surgery, despite negative results from other clinical and radiological tests for ovarian cancer. If other test results suggest cancer, referral to an oncologist is appropriate even with a negative OVA1 result. (FDA)OVA1 is only intended for women aged 18 and older who are already selected for surgery because of their pelvic mass. Interpreting test results requires knowing whether the woman has gone through menopause.

Sources: WebMD; Vermillion

Marker (Medline Search Terms): Proteomics

Organ (Medline Search Terms): OVA1

Medline Searches: neoplasm AND proteomics AND OVA1

Medline hits=1.

FDA Approved: Yes

### Gene Test Information: OvaCheck(TM), Ovarian cancer

Test Name: OvaCheck(TM)

Description: OvaCheck is based on the discovery that certain diseases, like ovarian cancer, are associated with a distinct protein pattern that can help in their detection. It looks for subtle changes in patterns among the tens of thousands of proteins, protein fragments and metabolites in the blood. It then employs an artificial intelligence-based computer technology to identify these hidden patterns.

Purpose: Diagnostic

Availability: Correlogic Systems, Inc.

Specimen: Blood

Methodology: Low-molecular-weight serum protein pattern recognition

Diseases: Ovarian cancer

Clinical Uses: Despite some promising findings, many health professionals still have concerns. They would like to see more published results of the test’s accuracy, and the labs that will perform the OvaCheck analyses still need to complete their own validation studies. Consequently, it will still be some time before it becomes available. Update 8 30 04: The FDA recently decided that the software used with the OvaCheck test is classified as a medical device and therefore is subject to its premarket review process. As a result, it will still be some time before OvaCheck becomes available. OvaCheck was developed as an additional tool for physicians for use in assessing women at high risk of ovarian cancer.

Sources: Lab Test Online (labtestsonline.org); www.correlogic.com

Marker (Medline Search Terms): OvaCheck

Organ (Medline Search Terms): (ovary or ovarian)

Medline Searches: neoplasm AND OvaCheck AND (ovary or ovarian)

Medline hits=3.

FDA Approved: No

### Gene Test Information: OvaSure(TM), Ovarian Cancer

Test Name: OvaSure(TM)

Description: OvaSure(TM), also known as the Yale Ovarian Cancer Test, is a six-marker ovarian cancer assay to identify candidate biomarkers to assess early stage ovarian cancer in high-risk women. The test includes leptin, prolactin, osteopontin, insulin-like growth factor II, macrophage inhibitory factor (MIF), and CA-125 in a multiplex immunoassay, as well as a calculated risk index. Each biomarker is weighted differently in the equation previously validated by clinical studies. A calculated risk index of 0.50 or greater indicates a positive reading, which is suggestive of ovarian cancer.

Purpose: Diagnostic

Availability: LabCorp (Laboratory Corporation of America)

Specimen: Serum, frozen

Methodology: Multiplex, bead-based immunoassay

Diseases: Ovarian Cancer

Clinical Uses: The OvaSure assay may be used as a tool to identify high-risk women who might have ovarian carcinoma. OvaSure is not indicated for a patient who is currently undergoing chemotherapy, who has had both ovaries removed, who is pregnant, or who is lactating.

Sources: LabCorp, OvaSure Techinal Review (https:www.newlabcorp.com (http://www.newlabcorp.com) wps wcm connect 7e0575004abea8aa8d9cbdce2e728548 L6367.pdf?MOD=AJPERES); LabHorizons, Volume VIII, No. 6, June 2008 (http:www.labcorp.com (http://www.labcorp.com) pdf LH6_2008.pdf)

Marker (Medline Search Terms): Yale Ovarian Cancer Test or Ovasure

Organ (Medline Search Terms): Ovary or ovarian

Medline Searches: neoplasm AND (Yale Ovarian Cancer Test or Ovasure) AND (ovary or ovarian)

Medline hits=77.

FDA Approved: Yes

## PROSTATE

### Gene Test Information: Bayer Immuno 1(TM) Complexed Prostate Specific Antigen, Prostate

Test Name: Bayer Immuno 1(TM) Complexed Prostate Specific Antigen

Description: Human prostate specific antigen (PSA) is a glycoprotein. PSA forms complexes with protease inhibitors such as alpha.sub.1 -antichymotrypsin (ACT) to form complexed PSA (cPSA). Concentrations of cPSA above 3.6 ng mL (nanograms per milliliter) are considered abnormally high, which indicates the possibility of prostate cancer.

Purpose: Diagnostic, monitoring

Availability: Commercial laboratories, academics

Specimen: Blood

Methodology: Immunoassay

Diseases: Prostate

Clinical Uses: The test is used in addition to a digital rectal examination (DRE). cPSA in combination with DRE detects significantly more cancer cases than DRE alone.

Sources: FDA

Marker (Medline Search Terms): Complexed Prostate Specific Antigen

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND Complexed Prostate Specific Antigen AND Prostate cancer

Medline hits=242.

FDA Approved: Yes

### Gene Test Information: deCODE Prostate Cancer, Prostate Cancer

Test Name: deCODE Prostate Cancer

Description: deCODE Prostate Cancer analyzes 25 genetic markers that have been associated with risk of prostate cancer in published, peer-reviewed studies involving tens of thousands of patients and control subjects from multiple populations (1–48). The risk conferred by each marker compared to that of the general population has been separately derived, replicated and validated. deCODE Prostate Cancer results apply only to men of European and African-American descent as the necessary scientific information to interpret the genetic risk for individuals of other ethnicities is not available. The website only mentions about two of the 25 markers.

Purpose: Diagnostic

Availability: deCODE diagnostics

Specimen: Buccal swab

Methodology: DNA amplification, hybridization and fluorescent detection

Diseases: Prostate Cancer

Clinical Uses: deCODE Prostate Cancer is a one time test that measures genetic risk of prostate cancer and can thereby help to establish an individual’s baseline risk.

Sources: deCODE diagnostics

Marker (Medline Search Terms): rs2710646 and rs1447295

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND rs2710646 and rs1447295 AND Prostate

Medline hits=1.

FDA Approved: No

### Gene Test Information: Hybritech(R) free PSA Test, Prostate cancer

Test Name: Hybritech(R) free PSA Test

Description: In the early 1990s, it was discovered that measuring the ratio of "free" to "total" PSA could further help in distinguishing prostate cancer from benign prostate disease. The Hybritech(R) free PSA test helps determine the percent of free PSA. The measurement of percent free PSA improves the accuracy of prostate cancer detection. The free PSA test is used following a non-suspicious DRE (digital rectal examination) and a total PSA test that shows moderately elevated PSA levels (between 4 and 10 ng mL) in men aged 50 years and older.

Purpose: Primary prevention, diagnostic

Availability: Beckman Coulter, Inc.

Specimen: Serum

Methodology: Immunochemistry, dual monoclonal antibodies

Diseases: Prostate cancer

Clinical Uses: The manual version of the Hybritech Total PSA test was the first to be approved by the FDA for monitoring patients diagnosed with prostate cancer. Then, FDA also approved for differentiating between cancer and benign conditions in men aged 50 years and older with total PSA between 4 and 10 ng mL and negative DREs.

Sources: Beckman Coulter, Inc. (http:www.beckmancoulter.com (http://www.beckmancoulter.com) products test detail access freepsa.asp)

Marker (Medline Search Terms): Free PSA

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND Free PSA AND Prostate

Medline hits=2753.

FDA Approved: Yes

### Gene Test Information: Progensa(TM) PCA3 Assay, Prostate cancer

Test Name: Progensa(TM) PCA3 Assay

Description: Progensa(TM) PCA3 Assay detects overexpression of the PCA3 gene in prostatic cells in urine sample, by means of mRNA quantification. Prostatic cells enter the urine stream and are collected in the first urine stream. Overexpression of the PCA3 gene has been associated with malignancy. The test results are theorized to be independent of prostate volume. It is suggested that this test is more specific than the serum PSA antigen.

Purpose: Diagnostic, prognostic prediction, therapeutic management

Availability: Commercial laboratories

Specimen: First urine collection after digital rectal exam with or without prostatic massage.

Methodology: TMA - transcription mediated amplification

Diseases: Prostate cancer

Clinical Uses: a) Routine: None. b) Investigational: add-on after digital rectal exam or PSA

Sources: www.pca3.org; www.gen-probe.com

Marker (Medline Search Terms): pca3[All Fields] AND ("research design" [MeSH Terms] OR ("research" [All Fields] AND "design" [All Fields]) OR "research design" [All Fields] OR "test" [All Fields] OR "laboratory techniques and procedures" [MeSH Terms] OR ("laboratory"[All Fields] AND "techniques" [All Fields] AND "procedures" [All Fields]) OR "laboratory techniques and procedures" [All Fields])

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND pca3[All Fields] AND ("research design" [MeSH Terms] OR ("research" [All Fields] AND "design" [All Fields]) OR "research design" [All Fields] OR "test" [All Fields] OR "laboratory techniques and procedures" [MeSH Terms] OR ("laboratory" [All Fields] AND "techniques" [All Fields] AND "procedures" [All Fields]) OR "laboratory techniques and procedures" [All Fields]) AND prostate

Medline hits=60.

FDA Approved: No

### Gene Test Information: Prostate-63, Prostate

Test Name: Prostate-63

Description: Monoclonal Mouse Anti-Human p63 Protein, Clone 4A4, antibody labels the nuclei of basal or progenitor cells in a variety of epithelia. The test may be a useful tool for the differential diagnosis of benign versus malignant prostatic lesions and for the identification of squamous cell carcinomas. Differential identification is aided by the results from a panel of antibodies.

Purpose: Primary prevention

Availability: Asymmetrxmedical and other commercial laboratories

Specimen: Liquid suspension of a cervical cell sample

Methodology: Immunocytochemistry

Diseases: Prostate cancer

Clinical Uses: Prostate-63 differentiates between benign and malignant prostatic lesions.

Sources: www.asymmetrxmedical.com

Marker (Medline Search Terms): Monoclonal Mouse Anti-Human p63 Protein

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND Monoclonal Mouse Anti-Human p63 Protein AND Prostate

Medline hits=0.

FDA Approved: No

### Gene Test Information: uPM3(TM) test; PCA3Plus test, Prostate cancer

Test Name: uPM3(TM) test; PCA3Plus test

Description: uPM3(TM) is based on PCA3, a specific gene that is profusely expressed in prostate cancer tissue (on average, 34 times greater than in benign prostate tissue). No other human tissues have ever been shown to produce PCA3.

Purpose: Prognostic predictive, therapeutic management

Availability: Bostwick Laboratories, DiagnoCure Inc

Specimen: Urine

Methodology: Immunocytofluorescent assay and Gene expression profiling

Diseases: Prostate cancer

Clinical Uses: PCA3Plus(TM) tests for prostate cancer cells that are shed into the urine. The rectal exam causes cells from the patients prostate to be shed into the urine, and the urine sample contains the released cells. If the sample is positive for PCA3, then the patient has a very high likelihood of having prostatic adenocarcinoma.

Sources: www.biospace.com

Marker (Medline Search Terms): PCA3

Organ (Medline Search Terms): Prostate

Medline Searches: neoplasm AND PCA3 AND Prostate

Medline hits=89.

FDA Approved: No

## Other

### Gene Test Information: LBA(R)AFP-L3, Hepatocellular Cancer

Test Name: LBA(R)AFP-L3

Description: LBA AFP-L3 is a lab test that helps determine the risk of developing liver cancer in patients with chronic liver disease (CLD). AFP is a glycoprotein with a single glycosylation site at a specific argininne residue. AFP-L3 fraction (the glycosylation variant that binds strongest to LCA) is produced predominantly by malignant cells. Liver cancer cells that express AFP-L3 have been shown to have an increased tendency for early vascular invasion and development of intrahepatic metastasis.

Purpose: Primary prevention

Availability: Wako diagnostics; other Commercial Laboratories

Specimen: Serum

Methodology: Liquid-phase binding assay

Diseases: Hepatocellular Cancer

Clinical Uses: LBA(R)AFP-L3 is used in the assessment of risk for the development of hepatocellular carcinoma (HCC) in patients with chronic liver diseases.

Sources: FDA, Labcorp

Marker (Medline Search Terms): Alpha-Fetoproteins

Organ (Medline Search Terms): Hepatocellular

Medline Searches: neoplasm AND alpha-Fetoproteins AND Hepatocellular

Medline hits=2976.

FDA Approved: Yes

### Gene Test Information: DakoCytomation c-Kit pharmDx(TM), Gastro-intestinal stromal tumors (GIST)

Test Name: DakoCytomation c-Kit pharmDx(TM)

Description: The antibody is used to identify c-KIT tyrosine kinase protein, a protein in the body that stimulates cancerous tissue cell growth. The presence of this protein establishes a diagnosis of GIST. The c-Kit pharmDxTM assay is a qualitative immunohistochemical (IHC) kit system used for the identification of c-kit protein CD 117 antigen (c-kit protein) expression in normal and neoplastic formalin-fixed paraffin-embedded tissues for histological evaluation. The c-kit pharmDxTM rabbit polyclonal antibodies specifically detect the c-kit protein in CD 117 antigen-expressing cells.

Purpose: Diagnosis and therapeutic management

Availability: Commercial and academic labs

Specimen: Tumor tissue

Methodology: Qualitative immunohistochemical (IHC) kit system with c-kit pharmDxTM rabbit polyclonal antibodies

Diseases: Gastro-intestinal stromal tumors (GIST)

Clinical Uses: Along with other pathological and clinical information establishes a diagnosis of GIST and indicates eligibility for treatment of GIST with the FDA-approved drug, Gleevec (imatinib mesylate)

Sources: FDA

Marker (Medline Search Terms): c-kit tyrosine kinase

Organ (Medline Search Terms): Gastro-intestinal stromal tumors

Medline Searches: neoplasm AND c-kit tyrosine kinase AND Gastro-intestinal stromal tumors

Medline hits=17.

FDA Approved: Yes

### Gene Test Information: MGMT methylation testing, Glioblastoma

Test Name: MGMT methylation testing

Description: O6-Methylguanine-DNA methyltransferase (MGMT) is an enzyme found in many normal tissues, including the brain. It is responsible for ensuring the quality of cellular DNA by repairing specific types of DNA injury. Several of the common treatments for gliomas, including alkylating agents such as temozolamide and carmustine, kill cancer cells by causing selective damage to tumor DNA. If the tumor is one which expresses MGMT, this damage may be undone, and the treatment will then be less effective or completely ineffective.

Purpose: Therapeutic management

Availability: OncoMethylome Sciences; LabCorp

Specimen: Blood or tumor tissue

Methodology: Immunohistochemistry

Diseases: Glioblastoma

Clinical Uses: Studies have shown that brain tumors lacking MGMT (either by IHC or by assessing promoter methylation) respond better to chemotherapy than those expressing MGMT.

Sources: www.oncomethmgmt.com

Marker (Medline Search Terms): MGMT

Organ (Medline Search Terms): Brain

Medline Searches: neoplasm AND MGMT AND Brain

Medline hits=363.

FDA Approved: No

## MULTIPLE

### Gene Test Information: CellSearch(TM), Breast colorectal and prostate cancer

Test Name: CellSearch(TM)

Description: The CellSearch(TM) System identifies and counts circulating tumor cells (CTC) of epithelial origin (CD45−, EpCAM+, and cytokeratins8, 18+, and or 19+) in whole blood to predict progression-free survival and overall survival in patients with metastatic breast, colorectal or prostate cancer, and can do so earlier than the current standard of care.

Purpose: Prognostic predictive, diagnostic, monitoring

Availability: Veridex, LLC

Specimen: Whole blood

Methodology: Immunomagnetic labeling and immunofluorescent identification of cells

Diseases: Breast colorectal and prostate cancer

Clinical Uses: The CellSearch(TM) System identifies and counts circulating tumor cells in a blood sample to predict progression-free survival and overall survival in patients with metastatic breast, colorectal or prostate cancer, and can do so earlier than the current standard of care. The results of serial testing for CTCs with the CellSearch(TM) System provide additional information to the oncologist and does so earlier than other currently approved diagnostic modalities, thereby allowing the oncologist to make more-informed patient care decisions.

Sources: www.medicalnewstoday.com; www.veridex.com

Marker (Medline Search Terms): CellSearch or Circulating tumor cells

Organ (Medline Search Terms): Breast or colorectal or prostate

Medline Searches: neoplasm AND (CellSearch or Circulating tumor cells) AND (breast or colorectal or prostate)

Medline hits=1960.

FDA Approved: Yes

### Gene Test Information: CupPrint, Cancer of Unknown Primary

Test Name: CupPrint

Description: Using a database of 51 different tumor types, CupPrint test can be applied to determine the gene expression profiling of the specimen and identify the tissue of origin. Prior studies have demonstrated that the cells of a distant majority retain vast majority of the gene expression characteristics of their originating site.

Purpose: Diagnostic

Availability: Commercial laboratories

Specimen: Tumor tissue

Methodology: Gene expression profiling

Diseases: Cancer of Unknown Primary

Clinical Uses: CupPrint aids in identifying primary tumor origin and thereby assists in the adequate treatment for tumors of unknown primary. Prior studies have shown that the tumor response varies substantially based on the tumor’s site of origin.

Sources: www.ferrerincode.com

Marker (Medline Search Terms): CupPrint

Organ (Medline Search Terms): Unknown Primary

Medline Searches: neoplasm AND CupPrint AND Unknown Primary

Medline hits=2.

FDA Approved: No

### Gene Test Information: DPD 5-FU GenotypR (TM), Multiple

Test Name: DPD 5-FU GenotypR (TM)

Description: Capecitabine is a chemotherapy drug that is given as a treatment for many types of cancer, including bowel cancer, breast cancer, stomach cancer and esophageal cancer. As a prodrug, capecitabine is selectively activated by tumor cells to its cytotoxic moiety, 5-fluorouracil (5-FU). Dihydropyrimidine deshydrogenase (DPD) is the main enzyme involved in the degradation of 5-FU. Decrease in DPD activity results in toxicity to 5-FU in cancer patients. An estimated 3-8% of patients have a genetic variation that leads to a deficiency of DPD. Patients with this variation have severe toxic reactions that may be fatal with even small doses and often the very first dose of 5-FU.

Purpose: Therapeutic management

Availability: Commercial laboratories

Specimen: Buccal swab

Methodology: PCR

Diseases: Multiple

Clinical Uses: The DPD test for 5-FU is considered appropriate for any person who is taking or considering 5-FU based chemotherapy. It is recommended that this screening be accompanied by direct measurement of DPD activity prior to 5-FU treatment in cancer patients.

Sources: PharmGKB

Marker (Medline Search Terms): Dihydropyrimidine deshydrogenase deficiency

Organ (Medline Search Terms): 5-Fluorouracil

Medline Searches: neoplasm AND Dihydropyrimidine deshydrogenase deficiency AND 5-Fluorouracil

Medline hits=2.

FDA Approved: No

### Gene Test Information: EGFRx(TM) assay, Multiple cancers

Test Name: EGFRx(TM) assay

Description: A new class of anti-cancer drugs selectively targets cells within the body that have a specific molecular defect that is believed to cause dangerous cell behaviors such as uncontrolled proliferative growth and high metastatic potential behaviors that typically are associated with aggressive cancer. The defect occurs within the interior of the cell in a region that is called the tyrosine kinase domain and it involves a complicated chemical process called EGFR signaling. The drugs are called anti-EGFR drugs or tyrosine kinase inhibitors. When the drugs work, they can be highly beneficial, causing tumor shrinkage or promoting stable disease and extending survival. However, as with most of the newer, targeted therapy drugs, tyrosine kinase inhibitors only work for a small percentage of the patients who receive them. In various studies, response rates in single agent and combined anti-EGFR drug therapy ranged from around 10% to 66%, depending upon the cancer type and the patient population involved. Further, the drugs are expensive and have been associated with toxic side effects. Finally, to make matters worse, no molecular (gene-based) test has been proven to tell reliably who will benefit from anti-EGFR treatment. In contrast, the Weisenthal Cancer Group EGFRx profile has been shown to correlate highly with patient response to anti-EGFR treatment and with overall patient survival. Reported prospectively, EGFRx profile results reliably identified patients who did or did not respond to treatment with anti-EGFR drugs and also those who achieved superior survival after treatment.

Purpose: Therapeutic management

Availability: Weisenthal Cancer Group

Specimen: Tumor cells

Methodology: "Whole Cell Profiling" in which living tumour cells are removed from an individual cancer patient and exposed in the laboratory to the new drugs

Diseases: Multiple cancers

Clinical Uses: The EGFRx targeted therapy profile includes analysis of the following targeted drugs: erlotinib (Tarceva), gefitinib (Iressa), sorafenib (Nexavar), and sunitinib (Sutent). For certain types of cancer, a drug called imatinib (Gleevec), which works in a very different way, may be tested. The finding is important because the EGFRx test, which can also be applied to many emerging targeted cancer drugs, could help to help to solve the growing problem of knowing which patients should receive costly, new treatments that can have harmful side-effects and which work for some but not all cancer patients who receive them.

Sources: http:www.weisenthalcancer.com (http://www.weisenthalcancer.com) Patient%20Pages EGFRXPatients.htm

Marker (Medline Search Terms): Tyrosine kinase

Organ (Medline Search Terms): Multiple organs

Medline Searches: neoplasm AND Tyrosine kinase AND Multiple organs

Medline hits=54.

FDA Approved: No

### Gene Test Information: miRview, Multiple cancers

Test Name: miRview

Description: miRview mets is a microRNA-based molecular diagnostic test designed to identify the origin of metastatic tumors with Cancer of Unknown Primary (CUP) patients in mind. miRview mets identifies 25 different tumor types, including lung, ovarian, testis, and prostate cancer.

Purpose: Diagnostic

Availability: Rosetta Genomics

Specimen: Formalin-fixed paraffin-embedded (FFPE), fresh frozen, serum, saliva, urine, and other body fluid samples

Methodology: microRNA

Diseases: Multiple cancers

Clinical Uses: Better identification of primary origin can: 1) Inform proper treatment selection 2) Spare patients unnecessary exposure to ineffective therapy

Sources: www.mirviewdx.com promets.html; http:www.mirviewdx.com (http://www.mirviewdx.com) innerData pdf mirvie_mets.pdf

Marker (Medline Search Terms): microRNA

Organ (Medline Search Terms): Cancer of Unknown Primary

Medline Searches: neoplasm AND microRNA AND Cancer of Unknown Primary

Medline hits=33.

FDA Approved: No

### Gene Test Information: Pathwork Tissue of Origin test, malignant tumor

Test Name: Pathwork Tissue of Origin test

Description: The Pathwork Tissue of Origin test compares the genetic material of a patient’s tumor with genetic information on malignant tumor types stored in a database. It uses a microarray technology to analyze thousands of pieces of genetic material at one time. The test considers 15 common malignant tumor types, including bladder, breast, and colorectal tumors.

Purpose: Diagnostic

Availability: Commercial Labs

Specimen: Tumor tissue

Methodology: Microarray or gene expression array

Diseases: Malignant tumor

Clinical Uses: Different types of cancers are classified based on the organs in which the tumors develop. With the help of microarray technology, these types of cancers can be classified in a standardized non-reader dependent manner based on the patterns of gene activity in the tumor cells.

Sources: FDA

Marker (Medline Search Terms): Pathwork

Organ (Medline Search Terms): Tissue of origin test

Medline Searches: neoplasm AND Pathwork AND Tissue of origin test

Medline hits=4.

FDA Approved: Yes

### Gene Test Information: PI3K, Multiple

Test Name: PI3K

Description: Activation of the phosphatidylinositol 3-kinase (PI3K)-AKT pathway, regulates many normal cellular processes which include cell proliferation, survival, and motility. PI3K signaling pathways can be deregulated by a variety of mechanisms in human tumors. Activation of the PI3K signaling pathway is frequently found in common human cancers, brought about by oncogenic receptor tyrosine kinases acting upstream, PTEN loss, or activating mutations of PI3K itself. Mutations in PI3K occur in a significant fraction of colorectal, breast, brain, lung and other tumor types. PI3K plays an essential role in tumor cell proliferation in adverse conditions as well as in invasion and metastasis.

Purpose: Prognostic and predictive

Availability: Clarient and other commercial laboratories

Specimen: Formalin-fixed paraffin-embedded tumor tissue

Methodology: Molecular: PCR

Diseases: Multiple

Clinical Uses: The test results suggest patients with tumors containing PI3K mutations may ultimately benefit from therapy directed at mutant PI3K or its downstream targets.

Sources: www.clarientinc.com

Marker (Medline Search Terms): PI3K oncogene

Organ (Medline Search Terms): neoplasm AND PI3K oncogene AND

Medline hits=1968.

FDA Approved: No

### Gene Test Information: TheraGuide 5FU (TM), Multiple

Test Name: TheraGuide 5FU (TM)

Description: Nearly 85% of 5-FU administered is metabolized by dihydropyrimidine dehydrogenase (DPD), rendering about 15% of the dose active. Variations in either the DPYD or TYMS genes increase the risk up to 60% during 5-FU treatment. TheraGuide 5FU (TM) is a comprehensive test for predisposition to 5-FU toxicity caused by variations in the DPYD and TYMS genes.

Purpose: Therapeutic management

Availability: www.myriadtests.com

Specimen: Blood

Methodology: PCR

Diseases: Multiple

Clinical Uses: Identifying patients with an increased risk for toxicity to 5-FU and capecitabine.

Sources: www.myriadtests.com

Marker (Medline Search Terms): DPYD OR TYMS

Organ (Medline Search Terms): capecitabine

Medline Searches: neoplasm AND DPYD OR TYMS AND capecitabine

Medline hits=13.

FDA Approved: No

### Gene Test Information: Tumor Profile, Multiple

Test Name: Tumor Profile

Description: The Tumor profile test allows identifying key amplifications and deletions across the genome. This can yield important information on key therapeutic oncogenes.

Purpose: Prognostic and predictive

Availability: Combimatrix

Specimen: Formalin fixed paraffin embedded tumor tissue

Methodology: Molecular: DNA array

Diseases: Multiple

Clinical Uses: The test is useful in a wide variety of tumors to yield prognostic and predictive information, which can further help in personalizing treatment for each individual patient.

Sources: www.combimatrix.com

Marker (Medline Search Terms): Oligonucleotide array sequence analysis OR DNA array

Organ (Medline Search Terms): Oncogene

Medline Searches: neoplasm AND (oligonucleotide array sequence analysis OR DNA array) AND Oncogene

Medline hits=2420.

FDA Approved: No