# Executive Summary

## Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) is interested in an update report of genetic tests for cancer conditions and the accompanying database to serve as a ready reference for their internal discussions in this area as well as the source for decisions on future topics for systematic reviews. CMS requested that the Technology Assessment Program (TAP) of the Agency for Healthcare Research and Quality (AHRQ) conduct an update of genetic tests for cancer conditions that were identified since the 2006 horizon scan report on Genetic Testing for Cancer. AHRQ assigned this project to the Tufts Medical Center Evidence-based Practice Center (Contract Number: HHSA 290 2007 10055 I, Task Order #3, work assignment #3).

The main objective of this report is to provide succinct information along with a preliminary estimate on the amount of published literature available on each identified genetic test through grey literature search since 2006. Systematic review of selected tests will be the subject of future focused reviews. The contents in the database and in this report reflect the data of genetic tests that were obtained from manufacturers’ Web sites or other commercial Web sites, and should not be construed as definitive clinical evidence or as recommendations for their routine clinical use.

## Methods

We adopted the 2006 horizon scan report Genetic Testing for Cancer Conditions (by the Tufts-EPC) as a model for this report. We adopted all the terminologies used in the previous report. We used the terminologies and definitions from the 2008 Report of the Secretary’s Advisory Committee on Genetics, Health, and Society (SACGHS) available at http://oba.od.nih.gov/.

### Inclusion criteria

We considered genetic tests that have applications in the common solid tumors (breast, lung, colorectal, pancreas, etc.) as well as tests that are used in hematologic cancers (leukemia, lymphoma). We included genetic tests that are already in clinical practice. The population of interest was adults with more applicability to the Medicare age group. We included genetic tests that are performed to aid in diagnosing, treating, predicting, prognosticating, monitor patient status and detect cancer recurrence. We also included genetic tests based on any one of the following selection criteria:

1. Genetic tests that have been cleared by FDA or pending clearance by FDA.
2. Genetic tests that are conducted in Clinical Laboratory Improvement Amendments (CLIA) certified labs and require a physician order.
3. Genetic tests offered by Internet sites that specifically require a physician order.

### Exclusion criteria

We excluded tests that are performed for conditions that exclusively result in early death before reaching adulthood. We also excluded tests performed for the purpose of identifying noncancer conditions.

### Clinical Applications of Genetic Tests

Genetic tests were further classified into diagnostic, prognostic, predictive, recurrence, and monitoring categories:

1. Diagnostic: used to confirm or aid in the diagnosis of the particular disease.
2. Prognostic: information from the test can be used to determine or predict the aggressiveness of the disease or overall outcome of the disease at the time of initial diagnosis and prior to initiation of treatment. Prognostic information can then be used to determine a particular or individualized treatment plan.
3. Predictive: information from the test can be used to determine or predict the response of the disease or overall outcome of the disease with treatment.
4. Recurrence: to detect disease recurrence in a patient who has already been diagnosed and treated for cancer.
5. Monitoring: test used to monitor tumor and/or patient response to treatment.

### Description of grey literature sources

The contents in this section were obtained directly from manufacturers’ Web sites or other commercial Web sites, and should not be considered as verified information. Some examples of grey literature sources include: GeneTests (genetests.org), Google News (news.google.com), Commercial diagnostic laboratories in the United States such as Roche Diagnostics^®^, Quest Diagnostics^®^, and LabCorp^®^, PHG Foundation (phgfoundation.org), EGAPP Reviews (egappreviews.org), and Association for Molecular Pathology (amp.org), and PharmGKB Web site (pharmgkb.org)

### Individual test summaries

Once the list of current genetic tests was identified, one-page summaries of each test in the database were completed using data extracted from various sources, including laboratory Web sites and test manufacturer Web sites. Data included in these summaries are a more detailed description of the test and its clinical use. The following items are included in the one-page summary: Test name, Description, Purpose, Availability, Specimen, Diseases, Clinical uses, Source, Marker (Medline Search Terms), Organ (Medline Search Terms), and Exploratory PubMed search.

### Description of the electronic database

We developed an in-house electronic database for efficient storage and retrieval of the aforementioned information on eligible genetic tests. We have created a My Structured Query Language (MySQL) (http://mysql.com/) database to store the collected genetic test information. The MySQL database created for this review stores and indexes all of the genetic tests. The Tufts-EPC is therefore developing a user-friendly interface to interact with the database, dubbed the ‘GeneTestTracker.’ The front end is Web-based, and written in the Python programming language (http://python.org/), using the Pylons (http://pylonshq.com/) Web framework. users can add a new genetic test by simply clicking the “add new” button. Furthermore, users can click on an existing gene test to bring up the corresponding one-page summary. This summary can then be edited or deleted by the user. Additionally, a Microsoft© Word-friendly Rich Text Format (RTF) document can be automatically generated from the summary page, which the user can download to their computer locally, or print out. We have also interfaced with PubMed so as to automatically generate the number of hits a search in PubMed turns up for a gene test over time.

### Updating of the database

The horizon scanning has been ongoing as a continuous process since 2007 and the database is being continuously updated. The results of grey literature along with one-pagers are sent to AHRQ quarterly. The relevance of the genetic tests and their evolution are assessed biannually.

## Results

Currently, the Gene Test Tracker database contains 112 different genetic tests logged into 161 test-disease combinations that are used in a variety of solid tumors and hematological cancers. We identified 50 new genetic tests for common cancer conditions since the 2006 report, with the largest number of tests being utilized for breast cancer, colorectal cancer, multiple cancers, lung cancer, and prostate cancer. Of these, 16 tests were identified through internet searches alone, 21 tests matured to clinical use of the 104 that were identified as tests “in development” in our 2006 report; and 13 tests were identified by experts during the peer review process. The one-page description for these newly identified genetic tests for cancer conditions can be found in Appendix A. Of the 104 tests that were identified as tests in development in our 2006 report, only 21 tests matured to full clinical use. One test (PyloriProbe) has been voluntarily withdrawn from the market, two tests that were identified as those used in the context of aspiration of cervical or breast specimens were excluded, and one test was excluded since it was identified as evaluating genetic material of infectious agent (digene High-Risk HPV HC2 DNA Test). The remaining 79 tests are currently being tracked as tests in development or in research. In addition, one test (PreGen Plus) which was identified as a test in clinical use in our 2006 report has also been withdrawn voluntarily from the market.

## Discussion

We identified 50 new genetic tests available for clinical use in cancer conditions since 2006. Of these, 16 tests were identified through internet searches alone, 21 tests matured to clinical use of the 104 tests “in development” in our 2006 report; and 13 tests were identified by experts during the peer review process. Recent grey literature searches indicate that the largest numbers of new tests were found in the breast, colorectal, and multiple cancer categories. Most of the information for each of the genetic tests was gathered from various public and proprietary Web sites. The laboratories offering genetic testing services provided most of the information on the description of the gene involved with the disease. Potential limitations of our report include lack of empirical structure providing guidance on how to conduct optimal grey literature searches of the Internet and Internet searches are not strictly reproducible. When compared to our previous 2006 report, the methodology of grey literature search is different, in that recent horizon scanning rely only on Internet searching without further contact with the companies. Currently, this process limits our ability to identify a test with multiple commercial names (for example, a test that has been licensed from one company to another company, but carries a different commercial name for the same test) or if changes are made to a test that retains the same name (for example, when additional single-nucleotide polymorphisms are added to a test).

This report of horizon scan for genetic tests for cancer conditions, with biannual updates, adds important information on emerging tests. Currently, there are attempts by different national agencies to summarize information on genetic tests. Until the NIH registry is fully effective, the current report is a valuable source of genetic tests that are in clinical use with specific applicability to older adults. Genetic testing is a rapidly emerging field with the potential to dramatically influence clinical decision-making. Health care providers, patients, payers, decision-makers, and consumers can benefit from staying abreast of newly-released tests.