# References

1 Khoury MJ, Dorman JS. The Human Genome Epidemiology Network. Am J Epidemiol. 1998;148:1-3. [pmid: 9663396].
2 Khoury MJ, Millikan R, Little J, Gwinn M. The emergence of epidemiology in the genomics age. Int J Epidemiol. 2004;33:936-944. [pmid: 15319400].
3 Chin KM, Wessler B, Chew P, Lau J. Genetic Tests for Cancer. http://archive.ahrq.gov/clinic/ta/gentests/. Evidence Report/Technology Assessment. 2006. Access date: March 2011.
4 Gwinn M, Grossniklaus DA, Yu W, Melillo S, Wulf A, Flome J, et al. Horizon scanning for new genomic tests. Genet Med. 2011;13:161-165. [pmid: 21233720].
5 Kuehn BM. NIH launching genetic test registry. JAMA. 2010;303:1685. [pmid: 20442379].